# GLOSSARY FOR OUTCOMES USED IN INCLUDED STUDIES

Acronym: Measure/Outcome
28 JC: Joint Count
AAMP: Australian Asthma Management Plan
AASA: Asthma Attitude Survey for Adults (24-item)
ABC: Activities-specific Balance Confidence
ABPM: Ambulatory Blood Pressure Monitoring
ADAPT: Arthritis, diet and physical activity promotion trial
ADDQOL: Audit of Diabetes-Dependent Quality of Life
AGKQ: Asthma General Knowledge Questionnaire
AHI: Arthritis Helplessness Index
AIMS2/Dutch-AIMS2: Arthritis Impact Measurement Scales version 2
AIMS2: AS: Arthritis Impact Measurement Scales version 2: Affect Subscale
AIMS2: CHS: Arthritis Impact Measurement Scales version 2: Current Health Subscale
AIMS2: PFS: Arthritis Impact Measurement Scales version 2: Physical Function Subscale
AIMS2: SS: Arthritis Impact Measurement Scales version 2: Symptom Subscale
ANCOVA: Analysis of Covariance
AQLQ: Asthma Quality of Life Questionnaire
AQOL: Assessment of Quality of Life
ASCQ: Arthritis Stages of Change
ASES: Asthma or Arthritis Self-efficacy Scale
ASMP: Arthritis Self-Management Program
BAI: Beck Anxiety Inventory
BASNEF: Belief, Attitude, Subjective Norm, Enabling Factors educational model
BAT: Behavioral Approach Test
BDI and BDI-II: Beck Depression Inventory
BIQ: Basic Information Quiz (51-item)
BMI: Body Mass Index
BRFSS: Behavioral Risk Factor Surveillance System
CBT: Cognitive Behavioral Therapy
CCQ: Clinical COPD Questionnaire
CES-D: Center for Epidemiologic Studies Depression Scale
CHANGE: Change Habits by Applying New Goals and Experiences
CHIP: Checklist for Interpersonal Pain Behavior
COCSC: Confidence in Overcoming Challenges to Self-Care instrument
COPE: Community-based physiotherapeutic exercise program
CORS: Coping With Rheumatoid Stressors
CQ: Asthma Knowledge Questionnaire (12-item)
CRDQ (aka CRQ): Chronic Respiratory Disease Questionnaire
CRQ-SAS: Chronic Respiratory Questionnaire Standardised
CSEQ: Cardiac Self-efficacy Questionnaire (two sub-scales)
DAS28: Disease Activity Score using 28 joint counts
DASI: Duke Activity Status Index
DCP: Diabetes Care Profile
DES-SF: Diabetes Empowerment Scale, Short Form
DHBM: Diabetes Health Belief Measure
DKQ: Diabetes Knowledge Questionnaire
DQIP: Diabetes Quality Improvement Program
DSMP: Diabetes Self-management Program
DTSQ: Diabetes Treatment Satisfaction Questionnaire
EADL: Extended Activities of Daily Living
EMIR: French Quality of Life of RA (using short version of AIMS2-SF)
EMS: Early Morning Joint Stiffness
EQ-5D: VAS: Five Dimensional Health State Description of EuroQol
ESR: Erythrocyte Sedimentation Rate
ESWT: Endurance Shuttle Walk Test
EURIDISS: EUropean Research on Incapacitating Diseases and Social Support
EuroQol: Euro Quality of Life
FaB scale: Falls Behavioural Scale (behaviors protective of falls)
FABQ: Fear Avoidance Belief Questionnaire
FACIT-F: Functional Assessment of Chronic Illness Therapy-Fatigue
FAST: Fitness Arthritis and Senior Trial
FBG: Fasting Blood Glucose
FEV: Forced Expiratory Volume
FFM: Percentage of Fat Free Mass
FIT: Educational and physical training program
FPI: Functional Performance Inventory
FSS-III-R: Distinguishes 5 types of fears/phobias
GCPS: Chronic Pain Scale
GDS: Geriatric Depression Scale
GHQ: General Health Questionnaire
GSES-16: General Self-Efficacy Scale
GV: Group visit
HAAS: Hypothetical Asthma Attack Scenarios
HADS: Hospital Anxiety and Depression Scale
HAQ: Health Assessment Questionnaire
heiQ: Health Education Impact Questionnaire
HJAM: Hand Joint Alignment and Motion Scale
HJC: Hand Joint Count
HOMA-IR: Homeostasis Model Assessment of Insulin Resistance
HRQOL: Health-related Quality of Life
HSI: Heaviness of Smoking Index
IDEA: Interactive Dialogue to Educate and Activate
IDEALL: Improving Diabetes Efforts Across Language and Literacy
IPAQ: International Physical Activity Questionnaire
IPQ-R: Revised Illness Perceptions Questionnaire
ISR: Index of Self-Religion
ISWT: Incremental Shuttle Walk Test
JP: Joint Protection
JPBA: Joint Protection Behavior Assessment
JPKA: Joint Protection Knowledge Assessment
K10: Kessler Psychological Distress Scale
KCCQ: Kansas City Cardiomyopathy Questionnaire
KSCDQ: Knowledge of Self-Care Demands Questionnaire
LASI: Left Atrial Size Index
LMAP: Lifestyle management for arthritis programme
LVDVI: LV Diastolic Volume Index
LVMI: Left Ventricular Mass Index
MAF: Multidimensional Assessment of Fatigue Scale
MAPT: Multi-Attribute Prioritisation Tool
MARS: Medication Adherence Report Scale (5-item)
mCTSIB: Modified Clinical Test of Sensory Interaction on Balance
MDS: Multidimensional Diabetes Scale
M-HAQ: Mobility-Health Assessment Questionnaire
MLHFQ (aka MLwHF): Minnesota Living With Heart Failure
MOCI: Maudsley Obsessive-Compulsive Inventory
MOS: Medical Outcomes Survey (measures of quality of life core survey)
MPLC: Multidimensional Pain Locus of Control Scale
MPQ: McGill Pain Questionnaire
MRC: Medical Research Council
NDI: Neck Disability Index
NHP: Nottingham Health Profile
NT-proBNP: N-terminal pro-brain natriuretic peptide
NYHA: New York Heart Association Classification
OT: Occupational therapist
PAID: Problem Areas in Diabetes Survey
PAM: Patient Activation Measure
PANAS: Positive and Negative Affect Schedule
PASE: Physical Activity Scale for the Elderly
PASS: Pain and stress self-management program
PCL: Pain Cognition List
PEF: Peak Expiratory Flow
PEM: Self-management empowerment education model
PIHAQ: Personal Impact Health Assessment Questionnaire
PSS: Perceived Stress Scale
PT: Physical therapist
QALYs: Stanford Health Assessment Questionnaire
QOL: Quality of life
RAI: AHS: Rheumatology Attitudes Index: Arthritis Helplessness Subscale
RAI: AIS: Rheumatology Attitudes Index: Arthritis Internality Subscale
RAND-36: RAND 36-Item Health Survey
RAQol: Rheumatoid Arthritis Quality of Life
RASE: RA Self-efficacy
RFS: Food Summary Score
ROM: Range of Motion
SCABPCQ: Self-Care Ability for Blood Pressure Control Questionnaire
SES: Self-efficacy Scale
SF-12: The 12-Item Short Form Health Survey
SF-36: Short Form Health Survey
SGRQ: St. George's Respiratory Questionnaire
SMART: Self-management arthritis relief therapy
SOPA: Survey of Pain Attitudes
SPSMQ: Short Portable Mental Status Questionnaire
SSAI: State Anxiety Inventory
SSES: Strengths Self-Efficacy Scale
STAI: Spielberger State-Trait Anxiety Inventory
TFEQ: Three Factor Eating Questionnaire
TICS: Telephone Interview for Cognitive Status
TSES: Total Self-efficacy Scale
TUG: Timed Up and Go
UAB: Pain Behavior Scale
UCL-DSMP: University College London-Diabetes Self-management Program
VAS: Visual Analog Scale
VNS: Visual Numeric Scale for pain (modified VAS)
VO2max: Maximal Oxygen Uptake
WHOQOL-BREF: World Health Organization quality of life instrument, short version
WOMAC: Western Ontario and McMaster Universities Osteoarthritis