# PEER REVIEW COMMENTS AND RESPONSES

Reviewer | Comment | Response
Q1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes. (No comment) | Noted.
2 | Yes. (No comment) | Noted.
3 | Yes. (No comment) | Noted.
4 | Yes. (No comment) | Noted.
5 | Yes. Detailed table of contents. Objectives are listed in the Executive Summary under the background information. | Noted.
6 | Yes. (No comment) | Noted.
7 | Yes. There was not really enough evidence but perhaps a weakness is that the groups run by peers and professionals could not be separated | Noted.
8 | Yes. (No comment) | Noted.
9 | Yes. Absolutely, very inclusive | Noted.
10 | Yes. (No comment) | Noted.
Q2. Is there any indication of bias in our synthesis of the evidence?
1 | No. No evidence for bias. | Noted.
2 | No. (No comment) | Noted.
3 | No. (No comment) | Noted.
4 | No. (No comment) | Noted.
5 | No. I felt that the review utilized a variety of databases to obtain a large number of articles related to group visits. Some of the studies looked at were done within the VA but in my opinion, the review did not provide any type of bias. | Noted.
6 | No. (No comment) | Noted.
7 | No. (No comment) | Noted.
8 | No. (No comment) | Noted.
9 | No, it was excellent | Noted.
10 | No. (No comment) | Noted.
Q3. Are the objectives, scope, and methods for this review clearly described?
1 | No. I am not aware of overlooked data sources. | Noted.
2 | No. (No comment) | Noted.
3 | Yes. Much of my focus has been intervention on blood pressure control in the group session, so some of the studies mentioned below have a slant towards treating hypertension. Appel, L.J., Chanpagne,C.M., Harsha, D.W., Cooper, L.S., Obarzanek, E., Elmer, P.J., Stevens, V.J., W.M., P. H., Svetkey, L.P., Stedman, S.W., Young, D.R., and Writing Group of the Premier Collaborative Research Group. 2003. Effects of comprehensive lifestyle modification on blood pressure control: main results of the Premier clinical trial. JAMA. 289:2083-2093 Baghianimoghadam, M.H., Rahaee, Z., Morowatisharifabad, M.A., Sharifirad, G., Andishmand, A., and Azadbakht, L. 2010. Effects of education on self monitoring of blood pressure based on BASNEF model in hypertensive patients. J RES MED SCI. 15:70-77 Cakir, H., and Pinar, R. 2006. Randomized controlled trial on lifestyle modification in hypertensive patients…including commentary by: Clark AM and response by Pinar and Cakir. West.J.Nurs.Res.28: 190-215 Palomaki, A., Miilunpalo, S., Holm, P., Makinen, E., and Malminiem, L. 2002 Effects of preventive group education on the resistance of LDL against oxidation and risk factors for coronary heart disease in bypass surgery patients. ANN.Med. 34:272-283 Saounatsou, M., Patsi, O., Fasoi, G., Stylianou, M., Kavga, A., Economou, O., Mandi, P., and Nicolaou, M. 2001. The influence of the hypertensive patient's education in compliance with their medication. Public Health Nurs. 18:436-442 | Two of the suggested papers (Cakir, Saounatsu) were a combination of group and individual visits, and it was impossible to separate out the effects of these respective intervention components. We examined the Palomaki study and decided against including it because the study design was not a randomized controlled trial. We agree that the Baghianimoghadam study should be included, which we have done, and have amended our results accordingly. We cited the Appel paper in the Limitation section as an example of a good quality study that combined group and individual visits without analyzing the group visit component separately, and clarified that we did not include these studies.
4 | No. (No comment) | Noted.
5 | No. Not that I am aware of. | Noted.
6 | No. (No comment) | Noted.
7 | Yes. Kearns, J.W. et al (2012) Group diabetes education administered through telemedicine: Tools used and lessons learned. Telemedicine and EHealth, 18, p347. | We examined the suggested study and decided against including it because the study design was not a randomized controlled trial.
8 | None of which I am aware | Noted
9 | No. Have you looked at the shared medical appointment esp or the realist review of evidence synthesis for shared medical appointments | We thank the reviewer for the suggestion. Yes, we have examined the shared medical appointment (SMA) ESP report and have noted that these reports are complementary reviews of group appointments. In addition, we developed our library in collaboration with the SMA group to ensure that there was no overlap in the included literature.
10 | No. (No comment) | Noted.
Q4. Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
2 | Page 10, last sentence-examples given of “non-prescribing providers only include “nurses and nurse educators” Although other disciplines are listed later, expanding the variety of disciplines in this sentence may more clearly show that it is not just a nurse-run group visit. | We have expanded the list of examples given on pg. 10, per the reviewer's suggestion.
3 | I must say I was disappointed that the great majority of studies fail to show a preponderance of evidence for the efficacy of the group medical experience versus standard treatment options in primary care, at least in the short-term. It appears that many studies showed some improvement in certain aspects such as blood pressure readings or a reduction in LDL numbers, but not very much evidence for long-term gains in overall physical health. It doesn't appear that there are enough studies done in a longitudinal fashion that would lend themselves to basing any conclusions of long-term gains. Being someone who believes in the group experience for patients, and who is continuing to use them in the form of drop in group medical appointments, or shared medical appointments under a heading of hypertension or diabetes, I was hoping for more evidence that would point to increasing the use of these types of clinic experiences. | We thank the reviewer for the thoughtful comments. We agree that there is a need for trials that evaluate outcomes over longer periods of time, and the utility of booster sessions. We have noted these gaps in the evidence base in the Future Research section.
6 | The review is very well written, including the Generalizability and Limitations sections. Page 60, last sentence, remove “the”, …to attend a multi-week course”… | We thank the reviewer for the feedback on the readability of the report, and have made the suggested change.
8 | In the last sentence on page 10 (Introduction Section), the report states, “This review . . .focuses exclusively on literature that tests the effectiveness of group visits that have an emphasis on health education and are led by non-prescribing providers such as nurses and nurse educators.” It is my understanding that the intent of the report is to review studies in which the group visits are led by non-prescribing health professionals (e.g., nurses, dietitians). Given this, should those studies described in the “Multiple Chronic Conditions” section (page 59) be included in this review since all but the Elzen (2007) study were led by peer leaders and not health care professionals? | We have included trials of group visits led by peer educators as well as social workers, and believe this is an important aspect to many group visit interventions that ought to be represented in the report. As a complement to the shared medical appointment report, this review was intended to expand the purview of group appointment interventions to include those led by personnel that are non-physicians. We have clarified that we include group visit facilitators that exclude prescribing providers and may include health professionals (e.g., nurses, dietitians, physical therapists).
8 | The recently released report on Shared Medical Appointments included a table in the “Future Research Section” that identified evidence gaps and suggested types of studies to close those gaps. Would it be possible to include a similar table in this report? | Yes, we agree that the Future Research section in table form, similar to the one used in the shared medical appointments report, is a useful way to display gaps in the research done in this area. We have made this change.
9 | This is definitely a contribution. I hope that in the discussion that you may add that areas that demonstrate some benefit but the studies are not strong, may be areas for further pilot testing in the field with more data collecting. I don't personally believe that the only answer is more rigorous studies, but more practice with the evidence we have. Patients' self efficacy and satisfaction with chronic disease care is critical for VA in the future when veterans can choose where they get their healthcare. Low cost options that may improve even short term outcomes may be worth investing in, especially when led by peers and in the community. I don't want to discourage that type of clinical care. Happy to talk further. Would be happy to be involved in writing a paper about this and comparing to sma ESP and sma realist review. | We thank the reviewer for the thoughtful comments. We have added suggestions for further pilot testing in the field and more efforts for data collection to the Future Research section.
10 | Here are some minor modifications.; 1. Changes to Group Visits Draft: Use of “dietitian” on pages 12, 47, 49, 86 – please spell with a “t” instead of a “c” in dietician; 2. In Generalizability section, last sentence- p. , suggest use of terminology “who demonstrated motivation “ instead of “who have enough motivation” which appears vague; 3. Limitations p. 71- “Knowledge improvement outcomes” instead of “knowledge outcomes” even if knowledge was not studied, the use of knowledge does not indicate any qualitative or quantitative changes | Noted. We have made these changes.
Q5. Are there any VA clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | Yes. Current primary care clinical performance is evaluated on percentage of encounters that are done in group setting, including educational and self management groups offered by nursing and other staff. I expect this will impact what conditions are treated in this fashion, with self-management preferred over didactic methods. | Noted.
2 | Not directly by this report but this report in conjunction with the SMA report from Durham may have an impact on SMAs in PACT. Could influence targets in Compass related to non-single provider face-to-face visits in PACT | Noted.
3 | Yes—there is certainly a “push” within the VA for expansion of the use of group medical appointments and shared medical appointments. Some of the focus in PACT (Patient Aligned Care Teams) within the VA is the use by the care team in fashioning unique and “out of the box” alternatives to the usual one patient-one provider-one visit model. There has also been a focus on applying evidence based practice measures to our daily practice in hopes of improving patient care. The VA will have to continue to look at group medical experiences, and the research that is available to determine how much emphasis is placed on the utilization of these particular experiences, as well as looking at the long term effects of these types of encounters to ascertain long-term benefit. | Noted.
5 | Group visits are listed under Access in the 2012 Compass Goals for VISN 12. Currently, groups are available for diabetes, lipids, CHF, and weight management. To meet access goals, groups allow more veterans to be seen in a timely manner. Individual appointment are also available, groups are not exclusive. | Noted.
6 | Not aware. | Noted.
7 | Many sites are implementing group education to meet performance measures for DM | Noted.
8 | Given that VHA has prioritized group visits as part of the new primary care model, staff who are members of PACT teams will be directly affected by this report. There are currently VA facilities where nurses are involved in group visits. In the next couple of weeks, the Office of Nursing Services, through the ONS liaisons to PACT and Specialty Care, will attempt to obtain a list of the sites that currently conduct group visits along with the target population for those group visits. Additionally, the national Diabetes Program, the national Pain Program, and the National Center for Patient Safety (falls) would likely be interested in this report. | Noted.
9 | This is a part of PACT and NCP. We can disseminate findings through them at a national level. Michael Goldstein and Margaret Dundon. | Noted.
Q6. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | It would be helpful to have data about what VA's are currently offering in relation to these conditions. | We agree that it would be helpful to discuss implementation of group visits and shared medical appointments within the context of what the VA currently offers for Veterans with chronic conditions. Although these considerations are important, this discussion this extends beyond the scope of this review.
2 | It would be helpful to not only know whether group visits affects the usage/frequency of traditional care but whether the traditional visit is altered when patients also attend group visits. For example, is the focus of the single provider face-to-face visit changed when patients also attend group visits (ie. patients that attend pain SMAs may still see their provider on the same schedule but they may be able to address more issues unrelated to pain whereas in the past the majority of the visit focused on pain-related issues). | This is a very interesting point. It would be an interesting premise for additional qualitative studies examining the quality of care provided in GVs as a complement to traditional individual clinical visits. We included studies of comparative effectiveness of head-to-head individual visits versus group visits. Unfortunately, there were few of these studies and we have identified this as a gap in the research base in the Future Research section.
3 | Happily the research does not seem to be saying that there is not benefit to the group experiences, but it does seem to point to the issue of perhaps longer studies being necessary. Also, how a patient perceives benefit from a group experience whether the data seems to show an actual “health benefit “is a much more nebulous and decidedly more difficult factor to measure. The VA will have to be prudent in using group experiences so that the focus continues to be looking to research to guide implementation of these appointments versus using these because of fiscal concerns. | We agree with the reviewer and have made these points in the Future Research and Discussion sections.
5 | Cost and specifically Medicare reimbursement have been the driving forces for group education in the private sector. In the VA, however, group education has been a means to improving better access—see more veterans in a timely manner. I am curious to know if length of class time (60, 90, 120min) or number of group visits(3-12 sessions) negatively influenced the group findings related to the 3 key questions? Individual visits might have been shorter (30-60 minutes) and only required 1 or 2 visits. Ultimately giving patients a choice in how they receive education— individual vs. group—is patient centric. A synthesized review showing that the results appear to be similar whether they receive individual or group education seem to support this new health care philosophy. I would encourage more research in the area of secured messaging and how that use of technology might affect patient outcomes in the management of chronic diseases. I would also encourage research in the area of MOVE! Groups and how they compare to individual visits. | We abstracted length and duration of group visits in the expectation that we would be able to compare trials based on these important elements. However, heterogeneity between trials was significant and precluded examination of these important questions. We agree that further research is needed and have identified various gaps in the Future Research section that the reviewer also identifies.
6 | As a geriatrician, my concern is that somewhat positive findings from RCTs of group appointments may not necessarily translate into improved outcomes in real life situation, given the selection bias inherent to characteristics of research participants in general (usually more motivated and concerned about their health). I just read a study from Netherlands that looked at older individuals' preferences for educational programs on falls and found that the majority (62.7%) had no interest to participate in any format; in addition, poor perceived health and age over 80 were associated with less preference for a group program format. (Dorresteijn, TA, Rixt Zijlstra GA, Van Eijs YJ, Vlaeyen JW, Kempen GI. Older people's preferences regarding programme formats for managing concerns about falls. Age Aging . 2012;41(4):474-81). It seems that given the weak evidence and the heterogeneity of intervention content and outcomes, the implementation of group appointments, especially in Geri PACTs, should not be rushed, because having to come in for a group appointment may not be the “most patient centered care” for a frail older individual. Also, additional evaluations should be incorporated early on, in this VHA implementation effort, so that meaningful conclusions could be made in the future on the value of group appointments in the VA. | The reviewer brings up some very important and interesting considerations. Although we did not find any direct harms, the VA should be cautious given the lack of robust findings that GV improve health outcomes. In addition, there is potential for downsides to GV implementation. For example, travel time involved to get to and participate in GVs, which as the reviewer points out, may be a salient and prohibitive factor for frail, older participants. Given the relatively low benefits in health outcomes and the risk of inconvenience, we need to be careful about making blanket recommendations of group visits, particularly for patient populations with specific health needs. We have included these points in the Discussion section.
9 | National PACT calls or community of practice | Noted.
Q7. Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Primary Care leadership, Mental Health leadership | Noted.
2 | Susan Kirsh, Sharon Watts | Noted.
6 | VACO GEC | Noted.
7 | PACT and Specialty care clinical teams will benefit HRSD should be aware of this as there is a gap in knowledge | Noted.
8 | As soon as the ESP program knows the date of the CyberSeminar when this report will be released, could you please send this information to Bev Priefer in the Office of Nursing Services so that we can do some advance notification of the various nursing groups that will be interested in this report. | Noted.
9 | Dr stark, dr schectman, me, dr kinsinger, dr Goldstein, ONS, Anthony morreale in pharmacy | Noted.
10 | Additional stakeholders include Primary Care Leaders to share with PACT teamlets and teams, and MOVE! Coordinators. The PACT and ACCESS goals promote the use of group education to manage chronic diseases. Additionally, individual visits are still available, offering Veteran's a choice. | Noted.