# QUALITY ASSESSMENT

## Definition of “good,” “fair,” and “poor” designations

Studies rated “good” have the least risk of bias, and results are considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” are susceptible to some bias, but it is not sufficient to invalidate results. These studies do not meet all the criteria for a “good” quality rating, but there is no indication that study flaws are likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The “fair” quality category is broad, and studies in this category can vary in their strengths and limitations. The results from fair studies range from valid to probably valid.

Studies rated “poor” have substantial flaws that imply biases in various rated categories that may invalidate results. They have a serious or “fatal” flaw in design, analysis, or reporting, including: large amounts of missing information, discrepancies in reporting, or raise serious concerns about the delivery of the intervention. The results of these studies are as likely to reflect flaws in the study design as they are to reflect true differences between compared groups. We did not exclude studies rated poor quality a priori, but poor quality studies were considered to be less valid than higher-quality studies when synthesizing the evidence, particularly when discrepancies between studies were present.

Appendix Table C1 Quality assessment and methodological characteristics of individual studies in randomized controlled trials of group visits

Table C2 Total number of outcome measures reported in studies of group visit interventions focusing on education for the management of chronic disease