# SEARCH STRATEGY

PubMed Searched on February 13, 2012

Set# (concept) | Search Strategy | Results
#1 (things being done) | (((“Health Education”[Mesh]) OR “Self Care”[Mesh]) OR (lifestyle[Title/Abstract] OR counseling[Title/Abstract] OR “self[Title/Abstract] AND management”[Title/Abstract] OR “health[Title/Abstract] AND coaching”[Title/Abstract] OR “motivational[Title/Abstract] AND interviewing”[Title/Abstract] OR diet[Title/Abstract])) | 393676
#2 (diseases of interest) | (hypertension[Title/Abstract] OR htn[Title/Abstract] OR chf[Title/Abstract] OR congestive[Title/Abstract] AND heart[Title/Abstract] AND failure[Title/Abstract] OR copd[Title/ Abstract] OR chronic[Title/Abstract] AND obstructive[Title/ Abstract] AND pulmonary[Title/Abstract] AND disease[Title/ Abstract] OR arthritis[Title/Abstract] OR pain[Title/Abstract] AND management[Title/Abstract] OR fall[Title/Abstract] AND risk[Title/Abstract]) OR ((((((“Hypertension”[Mesh]) OR “Heart Failure”[Mesh]) OR “Pulmonary Disease, Chronic Obstructive”[Mesh]) OR “Arthritis”[Mesh]) OR “Pain Management”[Mesh]) OR “Accidental Falls”[Mesh])) OR asthma OR “diabetes mellitus”[MeSH Terms] OR “diabetes”[Tiab] | 615989
#3 (group aspect) | (((group[Title] OR groups[Title] OR share[Title] OR shared[Title]) OR (“Self-Help Groups”[Mesh])) NOT ((“shared decision making”) OR (“focus group”) OR (“food group”))) | 163027
#4 (group aspect phrases) | “group education” OR “group attention control” OR “group sessions” OR “group therapy” OR “education group” OR “group program” OR “group programme” OR “group programs” OR “group programmes” OR “group interventions” OR “group exercise” OR “small group” OR “group strategy” OR “group relaxation” OR “group teaching” OR “group work” OR “group learning” OR “multidisciplinary intervention” OR “interdisciplinary intervention” OR “group session” OR “group patient visit” OR “nurse-led shared care” OR “nurse facilitated group” OR “group clinic” OR “group based self management” OR “peer led self management” OR “group or usual care” OR “group care” OR “peer led” | 46864
#5 (false phrases) | “age group” OR “study group” OR “research group” OR “working group” OR “group practice” OR “group home” OR “youth group” OR “group foster home” | 163923
#6 (group visits inclusive) | #3 OR #4 | 203980
#7 | #6 AND #2 AND #1 | 1133
#8 | #7 NOT #5 | 979
After deduplication from previous search | | 817

CINAHL (EBSCO) searched Monday, February 13, 2012 4:18:16 PM

Concept | Search Strategy | Results
Things being done | S8 S1 or S2 or S3 or S4 or S5 or S6 or S7 144186; S7 (MH “Diet+”) 49615; S6 (MH “Motivational Interviewing”) 758; S5 “health coaching” 68; S4 “self management” 4061; S3 (MH “Peer Counseling”) OR “lifestyle counseling” 618; S2 (MH “Self Care+”) 23157; S1 (MH “Health Education+”) 77695 | 144186
Diseases of interest | S18 S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or; S17 125262; S17 (MH “Accidental Falls”) OR “accidental falls” 10196; S16 “pain management” 6993; S15 (MH “Arthritis”) OR “arthritis” 21888; S14 (MH “Pulmonary Disease, Chronic Obstructive+”) OR “copd” 8106; S13 (MH “Heart Failure+”) OR “congestive heart failure” 19227; S12 “chf” 1736; S11 “htn” 153; S10 (MH “Hypertension”) OR “hypertension” 41268; S9 (MH “Asthma+”) OR “asthma” OR (MH”Diabetes+”) OR “diabetes” 22332 | 125262
Group | S44 S19 or S21 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 11958; S43 “group care” 103; S42 “group or usual care” 107; S41 “peer led self management” 7; S40 “group based self management” 5; S39 “group clinic” 12; S38 “nurse-led shared care” 7; S37 “group patient visits” 2; S36 “interdisciplinary intervention” 32; S35 “multidisciplinary intervention” 82; S34 “group learning” 167; S33 “group work” 701; S32 “group teaching” 114; S31 “group relaxation” 6; S30 “group strategy” 13; S29 “small group” 1763; S28 “group exercise” 692; S27 “group intervention” 794; S26 “group programme” 105; S25 “group program” 165; S24 “education group” 231; S23 “group therapy” 889; S22 “”group sessions” 0; S21 “group attention control” 2; S20 “”group education”” 0; S19 (MH “Group Exercise”) OR (MH “Support Groups+”) 7180 | 11958
False Phrases | S55 S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 20032; S54 “group foster home” 0; S53 “youth group” 14; S52 “group home” 142; S51 “group practice” 1642; S50 “working group” 1276; S49 “research group” 597; S48 “study group” 4509; S47 “food group” 180; S46 “focus group” 5757; S45 “age group” 6066 | 20032
| S8 and S18 and S44 128 | 128
| S57 S56 NOT S55 123 | 123
After deduplication from previous searches | | 90

Database: PsycINFO <1806 to February Week 1 2012>

Concept | Search Strategy
Things being done | 1. exp Health Education/ (12448); 2. exp Self Management/ or exp Health Promotion/ or exp Disease Management/ (17441); 3. exp Lifestyle/ or lifestyle counseling.mp. (6652); 4. health coaching.mp. (37); 5. exp Motivational Interviewing/ (800); 6. 1 or 2 or 3 or 4 or 5 (35296)
Diseases of interest | 7 asthma.mp. or exp Asthma/ (5016); 8 exp Hypertension/ or hypertention.mp. (4665); 9 exp Heart Disorders/ or congestive heart failure.mp. (9041); 10 copd.mp. or exp Chronic Obstructive Pulmonary Disease/ (951); 11 exp Rheumatoid Arthritis/ or exp Arthritis/ or arthritis.mp. or exp diabetes mellitus/ or diabetes.mp. (4170); 12 pain management.mp. or exp Pain Management/ (7290); 13 exp Falls/ or accidental falls.mp. (1089)
Group | 15 exp Group Discussion/ or exp Group Counseling/ (7568); 16 “group education”.mp. (252); 17 “group attention control”.mp. (2); 18 “group sessions”.mp. (1970); 19 “group therapy”.mp. (10895); 20 “education group”.mp. (419); 21 “group programme”.mp. (109); 22 “group program”.mp. (703); 23 “group intervention”.mp. (1995); 24 “group exercise”.mp. (164); 25 “small group”.mp. (6780); 26 “group strategy”.mp. (42); 27 “group relaxation”.mp. (55); 28 “group teaching”.mp. (174); 29 “group work”.mp. (3647); 30 “group learning”.mp. (698); 31 “multidisciplinary intervention”.mp. (104); 32 “interdisciplinary intervention”.mp. (46); 33 “group session”.mp. (492); 34 “group patient visits”.mp. (3); 35 “nurse-led shared care”.mp. (3); 36 “group clinic”.mp. (14); 37 “group based self-management”.mp. (3); 38 “peer led self management”.mp. (6); 39 “group or usual care”.mp. (5); 40 “group or usual care”.mp. (5); 41 “group care”.mp. (414); 42 “peer led”.mp. (356); 43 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 (32430)
False Phrases | 44 “study group”.mp. (2935); 45 “age group”.mp. (8248); 46 “research group”.mp. (1167); 47 “working group”.mp. (897); 48 “group practice”.mp. (456); 49 “group home”.mp. (782); 50 “youth group”.mp. (122); 51 “group foster home”.mp. (8); 52 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 (14552)
| 53 6 and 14 and 43 (55)
| 54 53 not 52 (55)
Deduplication | N=44 unique

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <January 2012>

Concept | Search Strategy
Things being done | 1. exp Health Education/ (7370); 2. exp Self Management/ or exp Health Promotion/ or exp Disease Management/ (5010); 3. exp Lifestyle/ or lifestyle counseling.mp. (1877); 4. health coaching.mp. (12); 5. exp Motivational Interviewing/ (0); 6. 1 or 2 or 3 or 4 or 5 (12310)
Disease of interest | 7 asthma.mp. or exp Asthma/ (18081); 8 exp Hypertension/ or hypertention.mp. (12184); 9 exp Heart Disorders/ or congestive heart failure.mp. (2610); 10 copd.mp. or exp Chronic Obstructive Pulmonary Disease/ (5428); 11 exp Rheumatoid Arthritis/ or exp Arthritis/ or arthritis.mp. or exp diabetes mellitus or diabetes.exp(8528); 12 pain management.mp. or exp Pain Management/ (1220); 13 exp Falls/ or accidental falls.mp. (617); 14 7 or 8 or 9 or 10 or 11 or 12 or 13 (47973)
Group | 15 exp Group Discussion/ or exp Group Counseling/ (0); 16 “group education”.mp. (203); 17 “group attention control”.mp. (15); 18 “group sessions”.mp. (445); 19 “group therapy”.mp. (905); 20 “education group”.mp. (289); 21 “group programme”.mp. (70); 22 “group program”.mp. (188); 23 “group intervention”.mp. (1350); 24 “group exercise”.mp. (428); 25 “small group”.mp. (662); 26 “group strategy”.mp. (8); 27 “group relaxation”.mp. (40); 28 “group teaching”.mp. (42); 29 “group work”.mp. (65); 30 “group learning”.mp. (42); 31 “multidisciplinary intervention”.mp. (50); 32 “interdisciplinary intervention”.mp. (18); 33 “group session”.mp. (86); 34 “group patient visits”.mp. (1); 35 “nurse-led shared care”.mp. (3); 36 “group clinic”.mp. (27); 37 “group based self-management”.mp. (4); 38 “peer led self management”.mp. (1); 39 “group or usual care”.mp. (156); 40 “group or usual care”.mp. (156); 41 “group care”.mp. (50); 42 “peer led”.mp. (128); 43 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 (4846)
False phrases | 44 “study group”.mp. (10409); 45 “age group”.mp. (1455); 46 “research group”.mp. (752); 47 “working group”.mp. (210); 48 “group practice”.mp. (165); 49 “group home”.mp. (82); 50 “youth group”.mp. (5); 51 “group foster home”.mp. (0); 52 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 (12995)
| 53 6 and 14 and 43 (175); 54 53 not 52 (167)