# REFERENCE LIST

1 WHO media centre. Diabetes. 2006;2001.
2 National Diabetes Information Clearinghouse. National Diabetes Statistics. 2005;2007.
3 Stratton IM, Adler AI, Neil HA, Matthews DR, Manley SE, Cull CA, et al. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. BMJ. 2000;321:405-12. [pmid: 10938048].
4 Faas A, Schellevis FG, Van Eijk JT. The efficacy of self-monitoring of blood glucose in NIDDM subjects. A criteria-based literature review. Diabetes Care. 1997;20:1482-6. [pmid: 9283802].
5 Coster S, Gulliford MC, Seed PT, Powrie JK, Swaminathan R. Self-monitoring in Type 2 diabetes mellitus: a meta-analysis. Diabet Med. 2000;17:755-61. [pmid: 11131099].
6 Welschen LM, Bloemendal E, Nijpels G, Dekker JM, Heine RJ, Stalman WA, et al. Self-monitoring of blood glucose in patients with type 2 diabetes who are not using insulin: a systematic review. Diabetes Care. 2005;28:1510-7. [pmid: 15920083].
7 Balk E, Teplinsky E, Trikalinos T, Chew P, Chung M, Pittas A. 20 Date of Publication. Maryland. Agency for Healthcare Research and Quality.
8 Jansen JP. Self-monitoring of glucose in type 2 diabetes mellitus: a Bayesian meta-analysis of direct and indirect comparisons. Curr Med Res Opin. 2006;22:671-81. [pmid: 16684428].
9 Furukawa TA, Barbui C, Cipriani A, Brambilla P, Watanabe N. Imputing missing standard deviations in meta-analyses can provide accurate results. J Clin Epidemiol. 2006;59:7. [pmid: 16360555].
10 Verhagen AP, de Vet HC, de Bie RA, Kessels AG, Boers M, Bouter LM, et al. The Delphi list: a criteria list for quality assessment of randomized clinical trials for conducting systematic reviews developed by Delphi consensus. J Clin Epidemiol. 1998;51:1235-41. [pmid: 10086815].
11 Suttorp M, Shekelle P, van Tulder M, Morton S, Bouter L. Cochran Back Group Quality Item and Bias in Back Pain Trials. Abstract.
12 Ray JW, Shadish WR. How interchangeable are different estimators of effect size?. J Consult Clin Psychol. 1996;64:1316-25. [pmid: 8991318].
13 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
14 Berkey CS, Hoaglin DC, Mosteller F, Colditz GA. A random-effects regression model for meta-analysis. Stat Med. 1995;14:395-411. [pmid: 7746979].
15 Hedges LV, Olkin I. Statistical Methods for Meta-Analysis. San Diego, CA. Academic Press Inc. 1985.
16 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327:557-60. [pmid: 12958120].
17 Stata Statistical Software Manual [computer program]. 2006. ed.
18 Atkins D, Best D, Briss PA, Eccles M, Falck-Ytter Y, Flottorp S, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328:1490. [pmid: 15205295].
19 Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81:830-6. [pmid: 3535493].
20 Fontbonne A, Billault B, Acosta M, Percheron C, Varenne P, Besse A, et al. Is glucose self-monitoring beneficial in non-insulin-treated diabetic patients? Results of a randomized comparative trial. Diabete Metab. 1989;15:255-60. [pmid: 2630378].
21 Estey AL, Tan MH, Mann K. Follow-up intervention: its effect on compliance behavior to a diabetes regimen. Diabetes Educ. 1990;16:291-5. [pmid: 2357919].
22 Allen BT, DeLong ER, Feussner JR. Impact of glucose self-monitoring on non-insulin-treated patients with type II diabetes mellitus. Randomized controlled trial comparing blood and urine testing. Diabetes Care. 1990;13:1044-50. [pmid: 2170088].
23 Rutten G, van Eijk J, de Nobel E, Beek M, van der Velden H. Feasibility and effects of a diabetes type II protocol with blood glucose self-monitoring in general practice. Fam Pract. 1990;7:273-8. [pmid: 2289639].
24 Muchmore DB, Springer J, Miller M. Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol. 1994;31:215-9. [pmid: 7888692].
25 Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. 1996;30:238-43. [pmid: 8833557].
26 Miles P, Everett J, Murphy J, Kerr D. Comparison of blood or urine testing by patients with newly diagnosed non-insulin dependent diabetes: patient survey after randomised crossover trial. BMJ. 1997;315:348-9. [pmid: 9270457].
27 Kibriya MG, Ali L, Banik NG, Khan AK. Home monitoring of blood glucose (HMBG) in Type-2 diabetes mellitus in a developing country. Diabetes Res Clin Pract. 1999;46:253-7. [pmid: 10624792].
28 Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25:259-68. [pmid: 11815493].
29 Schwedes U, Siebolds M, Mertes G. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care. 2002;25:1928-32. [pmid: 12401734].
30 Guerci B, Drouin P, Grange V, Bougneres P, Fontaine P, Kerlan V, et al. Self-monitoring of blood glucose significantly improves metabolic control in patients with type 2 diabetes mellitus: the Auto-Surveillance Intervention Active (ASIA) study. Diabetes Metab. 2003;29:587-94. [pmid: 14707887].
31 Kwon HS, Cho JH, Kim HS, Song BR, Ko SH, Lee JM, et al. Establishment of blood glucose monitoring system using the internet. Diabetes Care. 2004;27:478-83. [pmid: 14747232].
32 Davidson MB, Castellanos M, Kain D, Duran P. The effect of self monitoring of blood glucose concentrations on glycated hemoglobin levels in diabetic patients not taking insulin: a blinded, randomized trial. Am J Med. 2005;118:422-5. [pmid: 15808142].
33 Farmer A, Wade A, Goyder E, Yudkin P, French D, Craven A, et al. Impact of self monitoring of blood glucose in the management of patients with non-insulin treated diabetes: open parallel group randomised trial. BMJ. 2007.
34 Moher D, Pham B, Jones A, Cook DJ, Jadad AR, Moher M, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
35 Newman WP, Laqua D, Engelbrecht D. Impact of glucose self-monitoring on glycohemoglobin values in a veteran population. Arch Intern Med. 1990;150:107-10. [pmid: 2297280].
36 Malik RL, Horwitz DL, McNabb WL, Takaki ET, Hawkins HA, Keys AG, et al. Adjustment of caloric intake based on self-monitoring in noninsulin-dependent diabetes mellitus: development and feasibility. J Am Diet Assoc. 1989;89:960-1. [pmid: 2745914].
37 Klein CE, Oboler SK, Prochazka A, Oboler S, Frank M, Glugla M, et al. Home blood glucose monitoring: effectiveness in a general population of patients who have non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1993;8:597-601. [pmid: 8289098].
38 Rindone JP, Austin M, Luchesi J. Effect of home blood glucose monitoring on the management of patients with non-insulin dependent diabetes mellitus in the primary care setting. Am J Manag Care. 1997;3:1335-8. [pmid: 10178482].
39 Williams GC, McGregor H, Zeldman A, Freedman ZR, Deci EL, Elder D. Promoting glycemic control through diabetes self-management: evaluating a patient activation intervention. Patient Educ Couns. 2005;56:28-34. [pmid: 15590220].
40 Green LW, Glasgow RE. Evaluating the relevance, generalization, and applicability of research: issues in external validation and translation methodology. Eval Health Prof. 2006;29:126-53. [pmid: 16510882].
41 Norris SL, Lau J, Smith SJ, Schmid CH, Engelgau MM. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25:1159-71. [pmid: 12087014].