# METHODS

## Topic Development

This project was nominated by Dr. Chester B. Good, from the VA Pharmacy service for the Evidence Synthesis Project. Key questions were discussed and finalized during a conference call that included the Steering Committee of the Evidence Synthesis Project and the VA Greater Los Angeles project site director. The final key questions are:

1. Is regular SMBG effective in achieving target A1c levels for patients with type 2 diabetes?
2. Is regular SMBG effective in maintaining target A1c levels for patients with type 2 diabetes?
3. Does regular SMBG reduce the frequency of hypoglycemia in patients with type 2 diabetes?
4. Is there evidence that different frequencies of testing result in differences in improvements in A1c?

## Search Strategy

This topic has been the subject of several previous reviews.

Faas et al. (1997) 4 This review covered the years 1976–1996 and identified 11 studies from two Medline searches that met the inclusion criteria. Studies were excluded if they were not RCTs and if the patients were exclusively using insulin.

Coster et al. (2000) 5 This review covered the years 1990–1999 and originally identified 18 possibly relevant studies. Non-randomized studies were excluded. The review included eight randomized controlled trials. Two additional randomized trials were excluded; one because it used fructosamine as an outcome and the other because it used cluster randomization.

Welschen et al. (2005) 6 This review covered the years 1966 to 2004. A total of 36 articles were retrieved for further review of which five trials were included in the review. A total of six articles, one in press during the time of the initial search, were examined. Included trials looked at the effectiveness of SMBG compared with usual care in patients with type 2 diabetes who were not using insulin at the start of the trial and studies comparing SMBG and urine glucose monitoring.

Balk et al. (2006, draft report for AHRQ) 7 At the time we received this draft report by the Tufts-NEMC EPC it had only been distributed for the purpose of peer review and discussion at the Medicare Coverage Advisory committee meeting and had not yet been disseminated by the Agency for Healthcare Research and Quality. This review, dated August 16, 2006, identified five RCTs that evaluated SMBG with A1c as the outcome. Reasons for exclusion from this review were wrong population (type 1 diabetes), sample size too small (for inclusion n≥100 in the intervention arm), follow-up time too short (for non-clinical outcomes follow-up time had to be greater than or equal to three months), intervention or outcome not of interest, design (cross-sectional or retrospective), or the trial contained no primary data or duplicate data.

Jansen (2006) 8 This review covered the years 1966–2005. The review included studies that evaluated SMBG versus no self-monitoring, SMBG versus self-monitoring of urine glucose and SMBG with regular feedback versus monitoring without feedback. The review identified 27 studies that underwent quality assessment, from which 14 trials were excluded due to the outcome they assessed, type of diabetes included or the intervention was not clearly described.

The Balk et al. 7 review was not available to us at the start of this project. We judged the search strategy and inclusion/exclusion criteria of the review by Welschen et al. 6 to be comprehensive and therefore acceptable as the basis for our own review. We updated this search by searching PubMed from the end date of the prior search to October, 2006 and performed an update search in July 2007. The search strategy is listed below:

DATABASE SEARCHED & TIME PERIOD COVERED: PUBMED – 2004–2006

LIMITERS:

SEARCH STRATEGY:

Randomized Controlled Trail AND

Diabetes Mellitus, Type 2 AND

Blood Glucose self-monitoring

NUMBER OF ITEMS RETRIEVED: 23

In addition to our PubMed search and screening references from prior reviews, we also performed reference mining of retrieved articles.

## Study Selection

Two trained researchers reviewed the list of titles and selected articles for further review. The team of researchers consisted of two general internists, one with a special interest in diabetes. Each article retrieved was reviewed with a brief screening form (see Appendix A) that collected data on efficacy or effectiveness of SMBG alone or as part of a multi-component intervention, A1c and hypoglycemia reported as outcomes, the report of frequency of SMBG, duration of follow-up, study design, and whether or not the subjects in the study were Veterans. To be included in our evidence report, a study had to measure the efficacy or effectiveness of SMBG alone or as part of a multi-component intervention and have a follow up duration greater than or equal to 12 weeks (chosen because of the use of A1c as the outcome measure). Eligible study designs for efficacy included controlled clinical trials, RCTs, and systematic reviews/meta-analyses. Observational studies, case reports, non-systematic reviews, letters to the editor and other similar contributions were excluded as evidence of efficacy. To assess effectiveness, we required that studies assess SMBG in a Veteran population and VA healthcare delivery setting. RCTs and observational studies were eligible.

## Data Abstraction

Data were independently abstracted by two general internists trained in critical reading of the literature, with consensus resolution. The following data were abstracted from included trials: design; randomization and appropriateness; blinding and appropriateness; withdrawals and dropouts described; sample size enrolled and followed-up; characteristics of the population including percent women and race; mean, median, and range of age; mean, median and range of BMI; mean, median and range of duration of diabetes; reported comorbidities; sample size and intervention/exposure data for each arm of the study (intervention/exposure data included components of the intervention, total number of visits, frequency of SMBG, number of days per week monitored, duration of treatment, co-therapies); outcomes measured; intervals in which the outcomes were measured; adverse events. Data abstraction forms are provided in Appendix A. The mean A1c level and standard deviation was collected by treatment arm for each reported follow-up point. For trials that reported a mean outcome but no standard deviation, we estimated the standard deviation by taking the unweighted mean standard deviation across all other trials that reported standard deviations for the A1c level. 9

## Quality assessment

To assess internal validity of diagnostic studies, we used the Delphi criteria10 (see Appendix A). We abstracted data on treatment allocation; was the method of randomization performed and was the treatment allocation concealed; were the groups similar at baseline regarding the most important prognostic indicators; were the eligibility criteria specified; was the outcome assessor blinded; was the care provider blinded; was the patient blinded; were point estimates and measures of variability presented for the primary outcome measures; did the analysis include an intention-to-treat analysis. Our own work 11 supports using a threshold of four for distinguishing “high” versus “low” quality studies.

## Data Synthesis

Of the articles that were determined to be clinically eligible, duration of follow-up and frequency of SMBG were reviewed across studies to see if they were comparable.

Since the outcome of interest was the same across all trials, a mean difference was calculated for each time point that reported statistical data. The mean difference is the difference between the follow-up mean A1c level for the SMBG group and the follow-up mean A1c level for the control group. A negative mean difference indicates that the SMBG group has a lower mean A1c score than the control group. For our main analysis, we did not control for the baseline mean A1c for each group (a difference of differences estimate) since there is evidence that this approach is susceptible to bias. 12 We presented results controlling for the baseline as a sensitivity analysis.

A pooled estimate was calculated by follow-up time, in the following categories: 3–6months, 6–11 months, and 12 months or greater. The pooled estimate was calculated using the DerSimonian & Laird13 random effects model. In addition, we calculated a pooled estimate stratified by high and low quality trials.

Meta-regressions14 were performed to individually examine the effect of treatment frequency, quality score, and the baseline A1c mean on the mean difference. For trials with more than one follow-up time, the long term estimates were used. Test of heterogeneity were performed using Cochran’s Q15 and the I^2^ statistic. 16 A significant Q statistic or I^2^ values close to 100% represent very high degrees of heterogeneity. Publication bias was examined using the Begg rank correlation and Egger regression asymmetrytest. All analyses were conducted in Stata 9.2. 17

## Rating the body of evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grade Working Group, which classified the grade of evidence across outcomes according to the following criteria: 18

- ○ High = Further research is very unlikely to change our confidence on the estimate of effect.
- ○ Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- ○ Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- ○ Very Low = Any estimate of effect is very uncertain.

GRADE also suggests using the following scheme for assigning the “grade” or strength of evidence:

Criteria for assigning grade of evidence
Type of evidence
Randomized trial = high
Observational study = low
Any other evidence = very low
Decrease grade if:; - Serious (−1) or very serious (−2) limitation to study quality; - Important inconsistency (−1); - Some (−1) or major (−2) uncertainty about directness; - Imprecise or sparse data (−1); - High probability of reporting bias (−1)
Increase grade if:; - Strong evidence of association-significant relative risk of > 2 (< 0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1); - Very strong evidence of association-significant relative risk of > 5 (< 0.2) based on direct evidence with no major threats to validity (+2); - Evidence of a dose response gradient (+1); - All plausible confounders would have reduced the effect (+1)

For this report, we used both this explicit scoring scheme and the global implicit judgment about “confidence” in the result. Where the two disagreed, we went with the lower of the two classifications.

## Peer Review

A draft version of this report was sent to three peer reviewers. Their comments and our responses are presented in Appendix B.