# FUTURE RESEARCH

Our review of existing data support the short term beneficial effect of SMBG on A1c levels in the context of a clinical trial. Although improvement in A1c is modest, it is approximately equivalent to that achieved with diabetes education interventions. 41 Whether the benefit extends beyond six months is questionable.

However, observational studies in the VA do not report differences in A1c levels between Veterans using or not using SMBG supplies. This raises the question about implementation: more research is needed to understand if implementation of SMBG in a typical VA clinic setting is sufficient for Veterans to receive the full benefit reported in clinical trials.

In particular, it would be worthwhile to conduct studies in VA of “enhanced” SMBG versus usual care SMBG, with “enhanced” computer-based or nurse case-management or being Health Buddy or My Healthe Vet facilitated implementation of SMBG. This would more closely approximate the study question of interest today. New studies would also be able to account for improvements in SMBG technology (meters, strips, etc.) over time.

Additionally, data are needed about the cost-effectiveness of SMBG in a VA setting.

The evidence is insufficient to draw conclusions about which components of SMBG (additional-education, algorithms or other techniques to adjust medication) and frequency of testing are most associated with better results. More research is needed, and again we note that it should consider incorporation of methods for enhancing SMBG effectiveness. Additionally the impact of SMBG on medication adherence should be evaluated.