# EVIDENCE TABLE

Evidence Table 1 Randomized Controlled Trials Evaluating the Self-Monitoring of Blood Glucose

Author, Year | Sample Size Enroll/ Follow-up | Dur. of Diabetes inYears | Mean Age | Mean Weight (kg) / BMI | % Women / Race | Delphi List Quality Criteria | | | Arm/Group | | | | | Outcome | Adverse Events
Author, Year | Sample Size Enroll/ Follow-up | Dur. of Diabetes inYears | Mean Age | Mean Weight (kg) / BMI | % Women / Race | Method of Randomization | Eligibility criteria specified | Point estimates & measures of variability for primary outcome variable | Sample Size entering | Components | # Visit | Freq of SMBG Times/ Week | Dur. of Tx | Outcome | Adverse Events
Author, Year | Sample Size Enroll/ Follow-up | Dur. of Diabetes inYears | Mean Age | Mean Weight (kg) / BMI | % Women / Race | Allocation Concealment | Outcome assessor blind | Point estimates & measures of variability for primary outcome variable | Sample Size entering | Components | # Visit | Freq of SMBG Times/ Week | Dur. of Tx | Outcome | Adverse Events
Author, Year | Sample Size Enroll/ Follow-up | Dur. of Diabetes inYears | Mean Age | Mean Weight (kg) / BMI | % Women / Race | Similarity at Baseline between groups | Care provider blind | Did analysis included intention to treat analysis | Sample Size entering | Components | # Visit | Freq of SMBG Times/ Week | Dur. of Tx | Outcome | Adverse Events
Author, Year | Sample Size Enroll/ Follow-up | Dur. of Diabetes inYears | Mean Age | Mean Weight (kg) / BMI | % Women / Race | Similarity at Baseline between groups | Patients blinded | Did analysis included intention to treat analysis | Sample Size entering | Components | # Visit | Freq of SMBG Times/ Week | Dur. of Tx | Outcome | Adverse Events
WingRR et al., 1986 19 | 50 / 45 | NR | 54 | 98 / NR | 78% / NR | Yes | Yes | Yes | 25 | Exercise Counseling/Edu | 20 | Control | 62 wks | A1c Fasting Glucose BMI/Weight loss | ND
WingRR et al., 1986 19 | 50 / 45 | NR | 54 | 98 / NR | 78% / NR | No | No | No | 25 | SMBG Exercise Pt Control led Counseling/Edu | 20 | 5.4 | 62 wks | A1c Fasting Glucose BMI/Weight loss | ND
WingRR et al., 1986 19 | 50 / 45 | NR | 54 | 98 / NR | 78% / NR | No | No | No | 25 | SMBG Exercise Pt Control led Counseling/Edu | 20 | 5.4 | 62 wks | A1c Fasting Glucose BMI/Weight loss | ND
WingRR et al., 1986 19 | 50 / 45 | NR | 54 | 98 / NR | 78% / NR | No | No | No | 25 | SMBG Exercise Pt Control led Counseling/Edu | 20 | 5.4 | 62 wks | A1c Fasting Glucose BMI/Weight loss | ND
Fontbonne A et al., 1989 20 | 208 / 164 | 13 | 55 | 73 / 27 | 42% / NR | No | Yes | Yes | 68 | Counseling/Edu | 4 | Control | 6 mths | A1c BMI/Weight Loss | ND
Fontbonne A et al., 1989 20 | 208 / 164 | 13 | 55 | 73 / 27 | 42% / NR | No | No | No | 68 | SMBG Counseling/Edu | 4 | 7.5 | 6 mths | A1c BMI/Weight Loss | ND
Fontbonne A et al., 1989 20 | 208 / 164 | 13 | 55 | 73 / 27 | 42% / NR | Yes | No | No | 68 | SMBG Counseling/Edu | 4 | 7.5 | 6 mths | A1c BMI/Weight Loss | ND
Fontbonne A et al., 1989 20 | 208 / 164 | 13 | 55 | 73 / 27 | 42% / NR | Yes | No | No | 68 | SMBG Counseling/Edu | 4 | 7.5 | 6 mths | A1c BMI/Weight Loss | ND
Rutten G et al., 1990 23 | 149 / 127 | 8.1 | 63 | 75 / NR | 65% / NR | No | Yes | Yes | 83 | NR | NA | Control | 1 year | A1c BMI/Weight Loss | ND
Rutten G et al., 1990 23 | 149 / 127 | 8.1 | 63 | 75 / NR | 65% / NR | No | No | No | 66 | SMBG Dietician Counseling/Edu | Variable | NR | 1 year | A1c BMI/Weight Loss | ND
Rutten G et al., 1990 23 | 149 / 127 | 8.1 | 63 | 75 / NR | 65% / NR | No | No | No | 66 | SMBG Dietician Counseling/Edu | Variable | NR | 1 year | A1c BMI/Weight Loss | ND
Rutten G et al., 1990 23 | 149 / 127 | 8.1 | 63 | 75 / NR | 65% / NR | No | No | No | 66 | SMBG Dietician Counseling/Edu | Variable | NR | 1 year | A1c BMI/Weight Loss | ND
Muchmore DB et al., 1994 24 | 29 / 23 | 5 | 59 | 99 / 34 | 61% / NR | Yes | Yes | Yes | 14 | Dietician Counseling/Edu | 8 | Control | 44 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Muchmore DB et al., 1994 24 | 29 / 23 | 5 | 59 | 99 / 34 | 61% / NR | No | No | Yes | 15 | SMBG Dietician Counseling/Edu | 8 | 3 | 44 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Muchmore DB et al., 1994 24 | 29 / 23 | 5 | 59 | 99 / 34 | 61% / NR | Yes | No | Yes | 15 | SMBG Dietician Counseling/Edu | 8 | 3 | 44 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Muchmore DB et al., 1994 24 | 29 / 23 | 5 | 59 | 99 / 34 | 61% / NR | Yes | No | Yes | 15 | SMBG Dietician Counseling/Edu | 8 | 3 | 44 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Jaber LA et al., 1996 25 | 45 / 39 | 6 | 62 | 90 / 33 | 70% / African Ancestr y | No | Yes | Yes | 22 | NR | 2 | Control | 4 mths | A1c Fasting Glucose HRQOL^*^ | Hypoglycemia
Jaber LA et al., 1996 25 | 45 / 39 | 6 | 62 | 90 / 33 | 70% / African Ancestr y | No | No | No | 23 | SMBG Pt Controlled Counseling/Edu | NR | 8 | 4 mths | A1c Fasting Glucose HRQOL^*^ | Hypoglycemia
Jaber LA et al., 1996 25 | 45 / 39 | 6 | 62 | 90 / 33 | 70% / African Ancestr y | Yes | No | No | 23 | SMBG Pt Controlled Counseling/Edu | NR | 8 | 4 mths | A1c Fasting Glucose HRQOL^*^ | Hypoglycemia
Jaber LA et al., 1996 25 | 45 / 39 | 6 | 62 | 90 / 33 | 70% / African Ancestr y | Yes | No | No | 23 | SMBG Pt Controlled Counseling/Edu | NR | 8 | 4 mths | A1c Fasting Glucose HRQOL^*^ | Hypoglycemia
Kibriya MG, et al., 1999 27 | 64 / 64 | NR | 50 | 60 / 24 | 45% / NR | No | Yes | Yes | 32 | Counseling/Edu | 19 | Control | 18 mths | A1c Fasting Glucose | Hypoglycemia
Kibriya MG, et al., 1999 27 | 64 / 64 | NR | 50 | 60 / 24 | 45% / NR | No | No | No | 32 | SMBG Pt Control led Counseling/Edu | 7 | 1 | 18 mths | A1c Fasting Glucose | Hypoglycemia
Kibriya MG, et al., 1999 27 | 64 / 64 | NR | 50 | 60 / 24 | 45% / NR | No | No | No | 32 | SMBG Pt Control led Counseling/Edu | 7 | 1 | 18 mths | A1c Fasting Glucose | Hypoglycemia
Kibriya MG, et al., 1999 27 | 64 / 64 | NR | 50 | 60 / 24 | 45% / NR | No | No | No | 32 | SMBG Pt Control led Counseling/Edu | 7 | 1 | 18 mths | A1c Fasting Glucose | Hypoglycemia
Schwedes U, et al., 2002 29 | 250 / 223 | 5.3 | 60 | 89 / 31 | 48% / NR | Yes | Yes | Yes | 110+ | Counseling/Edu | 6 | Control | 24 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Schwedes U, et al., 2002 29 | 250 / 223 | 5.3 | 60 | 89 / 31 | 48% / NR | No | No | No | 113+ | SMBG Dietician Counseling/Edu | 6 | 12 | 24 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Schwedes U, et al., 2002 29 | 250 / 223 | 5.3 | 60 | 89 / 31 | 48% / NR | Yes | No | No | 113+ | SMBG Dietician Counseling/Edu | 6 | 12 | 24 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Schwedes U, et al., 2002 29 | 250 / 223 | 5.3 | 60 | 89 / 31 | 48% / NR | Yes | No | No | 113+ | SMBG Dietician Counseling/Edu | 6 | 12 | 24 wks | A1c BMI/Weight Loss HRQOL^*^ | ND
Guerci B, et al., 2003 30 | 988 / 689 | 8.1 | 62 | 83 / 30 | 45% / NR | No | Yes | Yes | 344+ | Counseling/Edu | 5 | Control | 6 mths | A1c Fasting Glucose | Hypoglycemia Other
Guerci B, et al., 2003 30 | 988 / 689 | 8.1 | 62 | 83 / 30 | 45% / NR | No | No | Yes | 345+ | SMBG Counseling/Edu | 5 | 6 | 6 mths | A1c Fasting Glucose | Hypoglycemia Other
Guerci B, et al., 2003 30 | 988 / 689 | 8.1 | 62 | 83 / 30 | 45% / NR | Yes | No | Yes | 345+ | SMBG Counseling/Edu | 5 | 6 | 6 mths | A1c Fasting Glucose | Hypoglycemia Other
Guerci B, et al., 2003 30 | 988 / 689 | 8.1 | 62 | 83 / 30 | 45% / NR | Yes | No | Yes | 345+ | SMBG Counseling/Edu | 5 | 6 | 6 mths | A1c Fasting Glucose | Hypoglycemia Other
Davidson MB, et al., 2005 32 | 89 / 88 | 5.6 | 50 | 82.3 / 32.5 | 74% / African Ancestry, Hispanic, Other | No | Yes | Yes | 45 | Dietician Other | 13 | Control | 6 mths | A1c BMI/Weight Loss | ND
Davidson MB, et al., 2005 32 | 89 / 88 | 5.6 | 50 | 82.3 / 32.5 | 74% / African Ancestry, Hispanic, Other | No | Yes | Yes | 43 | SMBG Dietician Other | 13 | 36 | 6 mths | A1c BMI/Weight Loss | ND
Davidson MB, et al., 2005 32 | 89 / 88 | 5.6 | 50 | 82.3 / 32.5 | 74% / African Ancestry, Hispanic, Other | Yes | Yes | Yes | 43 | SMBG Dietician Other | 13 | 36 | 6 mths | A1c BMI/Weight Loss | ND
Davidson MB, et al., 2005 32 | 89 / 88 | 5.6 | 50 | 82.3 / 32.5 | 74% / African Ancestry, Hispanic, Other | Yes | No | Yes | 43 | SMBG Dietician Other | 13 | 36 | 6 mths | A1c BMI/Weight Loss | ND
Farmer A et al., 2007^33^ | 453 / 453 | 3 | 66 | NR / 31.3 | 43% / NR | Yes | Yes | Yes | 152 | Usual Care | NR | Control | 12 mths | A1c BMI/Weight Loss | Hypoglyceima
Farmer A et al., 2007^33^ | 453 / 453 | 3 | 66 | NR / 31.3 | 43% / NR | Yes | No | Yes | 150 | SMBG | NR | 6 | 12 mths | A1c BMI/Weight Loss | Hypoglyceima
Farmer A et al., 2007^33^ | 453 / 453 | 3 | 66 | NR / 31.3 | 43% / NR | Yes | No | Yes | 151 | SMBG Patient Control | NR | NR | 12 mths | A1c BMI/Weight Loss | Hypoglyceima
Farmer A et al., 2007^33^ | 453 / 453 | 3 | 66 | NR / 31.3 | 43% / NR | Yes | No | Yes | 151 | SMBG Patient Control | NR | NR | 12 mths | A1c BMI/Weight Loss | Hypoglyceima

ND=Not Described, NR=Not Reported, NA=Not applicable,

* HRQOL=Health Related Quality of Life,

+ No entering sample size reported, this is the sample size completing the trial