# DATA COLLECTION FORMS

VA-EPC Self-Monitoring of Blood Glucose Article Screener

VA Self-Monitoring of Blood Glucose Project-Detailed Review Form

VA Male OP Project-Detailed Review Form-Diagnostic Studies

SMBG Project-Randomized Controlled Trials Quality Measurement