# SUMMARY AND DISCUSSION

We reviewed 1,363 titles and abstracts from the electronic search. 509 articles met inclusion criteria. Upon full text review, we excluded 416 articles, for a total of 94 included studies. We identified 47 primary studies for Key Question 1, 41 primary studies meeting inclusion criteria for Key Question 2, and 42 primary studies addressing Key Question 3. Thirty-two studies met criteria for more than one key question.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 What are the effects of financial incentive programs on patient outcomes and processes of care?

Overall, there is low to moderate evidence that P4P programs in ambulatory settings can improve the proportion of patients receiving the care process targeted by an intervention, though these effects are typically modest and not sustained over the long term, and findings vary according to study design and health system. Studies evaluating processes of care in the UK's QOF consistently report modest improvements in the first one to 2 years of the program, followed by either a plateau or slowing in improvement rates. In other ambulatory settings, a handful of studies, particularly those evaluating Taiwan's diabetes mellitus P4P program, report moderate improvements in processes of care associated with P4P, and findings from short-term and cross-sectional studies report generally positive associations between P4P and screenings and preventive care. However, findings from longer-term studies examining processes of care often report a slowing of improvement or little to no association.

There is no clear evidence of the QOF's effect on patient outcomes, with variation by indicator, disease condition, and study period. For some indicators, similar to findings reported for processes for care, the QOF had an immediate positive effect, with a plateauing of improvement over time. For others, such as HbA1c, post QOF trends were significantly below those predicted before the intervention. In other countries and in the United States, there is little good-quality evidence that directly examines the effects of P4P on health outcomes, with most studies reporting little to no effect.

In hospital settings, studies evaluating the Premier Hospital Quality Incentive Demonstration (HQID) and the Hospital Value-Based Purchasing (HVBP) programs in the United States report a limited effect on both processes of care and patient outcomes. However, a study evaluating the effect of P4P in the VHA on processes of care found significant and sustained improvement on 6 of the 7 measures examined. Internationally, studies evaluating hospital P4P programs report generally positive effects, with a slowing of improvements or a plateau over time.

### Key Question 2 What are the implementation factors that modify the effectiveness of pay for performance?

#### a What implementation factors are associated with changes in processes of care or patient outcomes?

We found 28 studies examining factors associated with processes of care or patient outcomes. We provide a more detailed summary of study and relevant key informant interview findings organized according to subcategories of the implementation framework in Table 15.

Table 15 KQ2 Evidence and Policy Implications by Implementation Framework Category

Implementation Framework Category | Study Evidence | Themes from KI Interviews | Policy Implications
Program design features | Thirteen studies2-14 examined program design features and found:; - Measures linked to quality and patient care were positively related to improvements in quality and greater provider confidence in the ability to provide quality care, with measures tied to efficiency were negatively associated.; - Perceptions of program effectiveness were related to the perception that measures aligned with organizational goals, and perceived financial salience related to measure adherence, as did perceptions of target achievability.; - Different payment models result in differences in both bonuses/payments and performance.; - More statistically stringent methods of creating composite quality scores was more reliable than raw sum scores; - The cost effectiveness of P4P varies widely by measure. | - Programs should include a combination of process of care and patient outcome measures.; - Process of care measures should be evidence-based, clear and simple, linked to specific actions rather than complex processes, and clearly connected to a desired outcome.; - Measure targets should be grounded in clinical significance rather than data improvement.; - Disseminate the evidence behind and rationale for incentivized measures.; - Measures should reflect the priorities of the organization, its providers, and its patients.; - Incentives should be designed to stimulate different actions depending on the level of the organization at which they are targeted.; - Incentives must be large enough to motivate, and not so large as to encourage gaming - with hypotheses ranging from 5-15%.; - Incentives should be based on improvements, and all program participants should have the ability to earn incentives.; - Magnitude of the incentive attached to a specific measure should be relative to organizational priorities. | - Programs that emphasize measures that target process of care or clinical outcomes that are transparently evidence-based and viewed as clinically important may inspire more positive change than programs that use measures targeted to efficiency or productivity, or do not explicitly engage providers from the outset.; - The incentive structure needs to carefully consider several factors including incentive size, frequency, and target.
Implementation Processes | Eight studies15-22 examined changes in implementation, with 7 specifically related to updating or retiring measures, and found:; - Under both the QOF and in the VHA, removing an incentive from a measure had little impact on performance once high level performance had been achieved.; - Increasing maximum thresholds resulted in greater increases by poorer-performing practices. | - Stakeholder involvement and provider buy-in are critical.; - Bottom-up approach.; - Reliable data/feedback to providers in a non-judgmental fashion.; - Consider distributing incentives to clinical and non-clinical staff. | - P4P programs should target areas of poor performance and consider de-emphasizing areas that have achieved high performance.
Outer Setting | Seven studies10,23-28 examined implementation factors related to the outer setting.; - There is no clear evidence that setting (eg, region, urban vs rural) or patient population predict P4P program success in the long term. | - Measures should be realistic within the patient population and health system in which they are used.; - Programs should be flexible to allow organizations to meet the needs of their patient populations. | - P4P programs should have the capacity to change over time in response to ongoing measurement of data and provider input.
Inner Setting | Eighteen studies7,24,26-41 examined implementation factors related to the inner setting. Studies found:; - For providers, being a contractor rather than being employed by a practice was associated with greater efficiency and higher quality.; - Under the QOF, practices improved regardless of list size, with larger practices performing better in the short term.; - Under the QOF there is limited evidence that group practice and training status was associated with a higher quality of care.; - Findings were less clear in the US and elsewhere with regard to practice size and training status. | - Resources must be devoted to implementation, particularly when new measures are introduced.; - Provide support at the local level including designating a local champion.; - Incentives are just one piece of an overall quality improvement program. Other important factors may include a strong infrastructure, organizational culture, allocation of resources, and public reporting.; - Public reporting is a strong motivator and future research should work to untangle public reporting from P4P. | - Programs that emphasize measures that target process of care or clinical outcomes that are transparently evidence-based and viewed as clinically important may inspire more positive change than programs that use measures targeted to efficiency or productivity, or do not explicitly engage providers from the outset.; - P4P programs should have the capacity to change over time in response to ongoing measurement of data and provider input.
Provider characteristics | Four studies5,23,39,42 examined characteristics of the individuals involved, and provided no strong evidence that provider characteristics such as gender, experience, or specialty play a role in P4P program success.

Note: Categories are not mutually exclusive.

#### b What implementation factors are associated with changes in provider cognitive and/or behavioral responses?

We included 14 studies examining factors associated with changes in provider cognitive and/or behavioral outcomes. Studies reported that perceptions of program effectiveness were related to measure alignment with goals, and that providers placing a higher degree of importance on goals and quality targets performed better than those who did not. In addition, measures focused on patient care experience or clinical quality improved staff communication and care coordination, while those focused on productivity or efficiency were associated with poor staff communication. One study found that provider participation in P4P programs relates to both the potential for rewards as well as perceived ethical risk, and another found differences in performance by underlying payment structure and concluded that higher incentives may be necessary when the degree of cost sharing is lower. Finally, the results of 2 small studies that surveyed providers on attitudes and values found a negative relationship between performance and placing a high value on autonomy.

KI discussions in this area centered on the balance between intrinsic and extrinsic motivation for providers and the organizational culture and support to align the two, including provider buy-in, and supportive and encouraging communication and feedback on provider performance. In addition, KIs stressed the importance of implementation processes, for programs in general and also for the introduction of newly incentivized measures. Implementation processes should be transparent and provide resources to encourage and enable provider buy-in through information that allows them to link the measure to clinical quality and provides guidance on how to achieve success. To further achieve buy-in, KIs urged the engagement of stakeholders of all levels at each stage, and recommended a “bottom-up” approach to program development. They stressed that P4P programs should include a combination of measures addressing processes of care and patient outcome, and that while measures should cover a broad range, too many measures increase the likelihood of negative unintended consequences. KIs also agreed that measures should reflect organizational priorities, be realistically attainable, evidence-based, clear, simple, and linked to clinically significant rather than data-driven outcomes, with systems in place for evaluation and modification as needed. In addition, improvements should be incentivized, incentives should be large enough to provide motivation but not so large as to encourage gaming, penalties may be more effective than rewards, and team-based incentives were suggested to increase the buy-in and professionalism of both clinical and non-clinical staff. Similarly, the timing of payments should be frequent enough to reinforce the link between measure achievement and the reward; however, this must be balanced with payment size, as the reward must be substantial enough to reinforce behavior.

### Key Question 3 What are the positive and negative unintended consequences, including any effect on health disparities, associated with pay for performance?

Forty studies examining unintended consequences associated with P4P met inclusion criteria for Key Question 3, of which 33 evaluated the QOF. Among these studies, 28 of the 40 evaluated the effect of P4P on health disparities in populations of low socio-economic status or racial/ethnic minorities, or examined disparities associated with other characteristics such as age, and multiple conditions. Nineteen studies report findings related to other unintended consequences, such as, gaming, positive and negative effects on unincentivized areas of care, and cherry picking/risk selection.

#### Health Disparities

Most of the studies examining differential effects of P4P by race/ethnicity, socioeconomic, or other demographic characteristics came from the UK's QOF program. In general, there was no strong consistent evidence that P4P had different effects on different patient subgroups, though there were some exceptions as detailed in the main report. Groups with lower baseline care quality tended to experience greater absolute levels of improvement over the short term.

Key informants in the UK noted that, in the first 2 years after its introduction, the QOF successfully decreased health disparities. This was due to the larger magnitude of improvements seen among practices in areas of high deprivation which tended to have lower baseline levels of performance. However, key informants also noted that, once practices were performing near the upper thresholds, the costs associated with eliminating the remaining gaps were higher in areas with higher deprivation, and that providers in more affluent areas were more likely to receive incentives.

In the United States, the relationship between P4P and health disparities has not been well-studied. A number of KIs stressed the lack of formal evaluation of health disparities in US programs, the importance of the collection of cultural variables to allow for an accurate assessment, and the need for consistency across measures to allow for formal evaluation.

#### Other Unintended Consequences

##### Gaming

We found very few studies which directly examined the issue of gaming. Two studies examined preferential recording of values within the QOF, with one study reporting an increase of values just below a newly introduced target, and another study reporting no evidence of gaming. Key informants stressed that gaming is likely to occur and that P4P programs should be designed with this assumption. In general, KIs felt that, to reduce the likelihood of gaming, P4P programs must have stakeholder input and buy-in, and should be based on precise, simple, evidence-based, and realistic measures.

##### Risk selection

A number of studies examined risk selection associated with the QOF. One study found a positive relationship between the rate of exception reporting and total QOF score, and another study found significantly higher levels of quality in patients who were not excluded as compared with all patients, particularly for more complex processes and treatment related indicators.

Studies report higher rates of exception reporting for non-white, low-income patients, and patients with more co-morbid disorders, with one study reporting a higher percentage of excluded patients in larger practices. However, another concluded that higher rates of exception reporting were due to better documentation associated with the QOF. In Taiwan, non-enrolled patients were older, had more co-morbid conditions, and had higher diabetes risk scores. Key informants in the UK felt that exception reporting was not being abused. In the United States, key informants expressed concern that higher-risk patients can now be easily identified using algorithms, and a common theme among KIs was that incentive payments should be risk-adjusted to account for higher-risk patients.

##### Spillover effects

We found evidence of both positive and negative impacts of P4P on unincentivized measures as well as to unincentivized populations. One QOF study found that, over 3 years, the rate of improvement in areas or populations not associated with incentives declined. However, other studies in both the UK and the US reported positive effects on unincentivized care. For example, one study reported a positive spillover of a 10.9% increase in the recording of unincentivized indicators for patients with targeted disease conditions in the QOF. Key informants agreed that spillover effects likely occur, and suggested that the lack of significant findings associated with Centers for Medicare and Medicaid Services' (CMS) Hospital Value-Based Purchasing (HVBP) program was due to improvements in quality spilling over to control hospitals.

#### Study Characteristics and Quality

We used a best evidence approach to guide study selection, and the Newcastle Ottawa Scale to rate study quality. All of the studies examining processes of care or patient outcomes (KQ1) had either sample sizes of 10,000 patients or more, or were longitudinal with 3 or more time points to allow for a trend. The studies examining larger P4P programs were most often retrospective cohort or cross-sectional studies with large sample sizes using simple pre-post designs or stronger methods such as difference in difference or interrupted time series. For studies that did involve comparison groups, not all utilized matched samples, and the inherent heterogeneity precludes strong conclusions. For key question 2, we included studies with less rigorous designs and smaller samples to allow us to better capture the breadth of research examining factors relate to the implementation of P4P programs. We included similar studies for key question 3 to allow for studies examining smaller subpopulations.

#### Publication Bias

Given that this review topic focuses on health systems rather than clinical interventions, no studies reported registered protocols, nor did studies report a priori primary aims or analyses. We did conduct a search for grey literature; however, we were unable to formally assess for publication bias.

#### Heterogeneity

Studies included in this review represent a wide range of P4P programs in a variety of settings, with vast differences in program characteristics and implementation features. Heterogeneity precluded us from combining studies quantitatively. Instead, study detail is provided in evidence tables and we provide a qualitative synthesis of study findings.

## DISCUSSION

We found 94 studies conducted in the United States and other countries that could inform practice in the VHA. The studies we examined across all 3 Key Questions differed widely by health system and patient population, and evaluated a range of P4P programs that varied substantially in both measures prioritized and incentive structure. Despite numerous examples of P4P programs, the heterogeneity inherent to each health system and organization, and the challenges related to the evaluation of complex interventions such as P4P, preclude us from drawing strong conclusions that can be broadly applied.

While the literature does not provide strong evidence to definitively guide the implementation of P4P programs, there are several themes from KI interviews that were consistent with evidence from the published literature. First, programs that emphasize measures that target process of care or clinical outcomes that are transparently evidence-based and viewed as clinically important may inspire more positive change than programs that use measures targeted to efficiency or productivity, or that do not explicitly engage providers from the outset. Findings from both the literature examining physician perceptions and KI interviews support the use of evidence-based measures that are congruent with providers expectations for clinical quality, and there was a strong agreement among KIs that provider buy-in is crucial.

Second, the incentive structure needs to carefully consider several factors including incentive size, frequency, and target. In general, the QOF, with its larger incentives, has been more successful than programs in the US Key informants attribute this to incentives that are large enough to motivate behavior, but also caution that larger incentives may not be cost-effective and may result in gaming. KIs also stressed the importance of the attribution of the incentive to provider behavior, that incentivized measures should be congruent with institutional priorities, should address the needs of the institution at the local level, and should be designed to best serve the local patient population.

Third, P4P programs should have the capacity to change over time in response to ongoing measurement of data and provider input. Key informants strongly agreed that P4P programs should be flexible and evaluated on an ongoing and regular basis. They pointed to the QOF, which is evaluated annually, and which has undergone numerous adjustments since its inception, such as the measures incentivized and the thresholds associated with payments.

Finally and relatedly, P4P programs should target areas of poor performance and consider de-emphasizing areas that have achieved high performance. Findings from studies of both the QOF and the VHA and our KI interviews support that improvements associated with measures achieving high performance can be sustained after the measure has been de-incentivized. Consistent evaluation of the performance of, and adjustments to incentivized measures will allow institutions to shift focus and attention to the areas of greatest need for improvement.

### Recommendations for Future Research

Despite numerous P4P programs in the United States, the United Kingdom, and elsewhere, there is a need for higher-quality evidence to better understand whether these programs are effective in improving the quality of healthcare and patient health, and whether they result in negative unintended consequences. Studies examining P4P have been largely observational and primarily retrospective; thus, despite large sample sizes, the nature of these study designs prevents the forming of strong conclusions that can be broadly applied. In addition, comparative studies that do exist often lack good matched comparison groups, with program sponsors reluctant to engage in random assignment or delay implementation to create a comparison group of providers. One of the fundamental challenges in evaluating complex multi-component interventions such as P4P is disentangling the individual effect of each intervention. In the case of P4P, the challenge is even greater, as contextual and implementation factors must also be strongly considered, as programs differ widely in their measures and incentive structures, as do the overarching health systems and organizations to which they are applied, and the patient populations for which they are designed to serve. Based on our review of the literature, insight provided by our key informants, and including future research needs salient to the VHA that were explicitly expressed by our KIs, we highlight the following:

- What is the effect of P4P without the influence of public reporting, and is this even important? Are there certain circumstances in which public reporting has a stronger or weaker influence (eg, is public reporting more influential at the hospital/administrative level, thus leading to greater structural changes vs behavior change at the individual provider level)?
- Are there an optimal number of measures needed to improve quality across a broad range of care, yet not encourage unintended consequences?
- Is there an incentive size and structure (rewards vs penalties, frequency, etc) that optimizes motivation for providing high-quality care, while balancing intrinsic and extrinsic motivation?
- What is the influence of the underlying payment structure on the effectiveness of P4P and the avoidance or mitigation of unintended consequences? Are there types of measures or incentive structures that are better for some, but not all payment structures?
- Are provider-level P4P incentives that target individual providers or teams more effective at improving the overall quality of care?
- Does P4P differentially affect subpopulations of patients (eg, low income, racial/ethnic minorities, patients with multiple co-morbidities)? If so, what can be done to mitigate health disparities and to avoid unintended consequences such as gaming and risk selection?
- Future research should examine the role of provider cultural sensitivity and the potential response bias on patient surveys/questionnaires related to differences in language and culture, and how these factors may influence performance and outcomes.
- Mixed-methods research should be conducted with a variety of stakeholders to provide a deeper understanding of factors related to implementation and unintended consequences.
- Future research should explicitly examine negative unintended consequences associated with pay for performance, including but not limited to gaming (including denominator gaming) and risk selection.
- Future research should report detail regarding the context and setting as well as incentive and implementation factors associated with the P4P program.
- Future research should examine the role and utility of stakeholders and all levels in the development of pay for performance programs and subsequent effect on patient health outcomes.
- Finally, KIs stressed the belief that the VHA as a system is in a unique position from which to conduct much-needed rigorous and methodologically strong P4P research, examining not only P4P's effectiveness on processes of care and patient outcomes, but also examining implementation characteristics and unintended consequences.

### Limitations

Our review has a number of limitations. Due to the recent report on pay for performance programs published by the RAND Corporation and commissioned by CMS, which focused largely on programs in the United States, and our inclusion of studies examining the UK's Quality and Outcomes Framework, our review and subsequent conclusions are weighted heavily towards programs targeting ambulatory care. In addition, given the heterogeneity in P4P programs, and our goal of not only evaluating the effectiveness of P4P on the quality of care and patient health, but also of better understanding the important factors related to implementation and unintended consequences (particularly for Key Questions 2 and 3), we included studies that utilized less-rigorous methodology, some of which had small samples. The breadth of topics and outcomes related to implementation characteristics made it difficult to restrict our criteria by study design. Due to these factors, along with studies examining primarily observational data, we did not formally assess strength of evidence. To better inform an understanding of implementation factors important to the success of P4P programs, we interviewed 14 key informants. As our goal was not to conduct primary research, our key informants were experienced P4P researchers in the United States and the United Kingdom. While their knowledge and experience provided us with insight into implementation processes and unintended consequences, and they were particularly well positioned to speak to future research needs, we recognize that that conversations with other stakeholders, such as policymakers, program officials, hospital administrators and managers, providers and other clinical and non-clinical staff, and patients, are necessary to more fully understand the issues related to P4P.

### Conclusions

Despite a large number of studies examining the effect of P4P on processes of care and patient outcomes, it is difficult to identify strong, broadly applicable conclusions about the effects of P4P programs. In part, this is because of the wide variation in health systems, patient populations, incentive structures, and underlying payment mechanisms represented across studies. In addition, studies were largely retrospective and observational in nature, or lacked adequate matched comparison groups. In general, P4P programs appear to have the potential to improve process of care outcomes over the short term, especially in ambulatory settings. There is insufficient evidence that P4P programs have beneficial effects on care processes over the long term, or on patient outcomes over any time period. Incentive programs tend to have the greatest absolute effect on care processes over the short term in settings with lower baseline levels of performance. In the United States in particular, the effects of P4P on health disparities are unclear, largely due to the lack of patient cultural variables collected and recorded. There is limited evidence in the VHA that initial improvements may sustain even after removal of the incentive. The value of incentive programs to stimulate incremental performance gains once initial improvements have been achieved is unclear. Also unclear is the influence of P4P above and beyond other quality initiatives often accompanying financial incentives, such as public reporting and information technology. Findings from experts in the field are congruent with previous qualitative work133 – that the potential negative unintended consequences of P4P may outweigh benefits in these circumstances, though there is relatively little good-quality evidence examining the rates of harms from P4P.