# REFERENCES

1 Damberg C, Sorbero M, Lovejoy S, Martsolf G, Raaen L, Mandel D. Measuring Success in Health Care: Value-Based Purchasing Programs. Findings from an Environmental Scan, Literature Review, and Expert Panel Discussions. Santa Monica, California. 2014.
2 Walker S, Mason AR, Claxton K, et al. Value for money and the Quality and Outcomes Framework in primary care in the UK NHS. The British journal of general practice : the journal of the Royal College of General Practitioners. May. 2010;60(574):e213-220. [pmid: 20423576].
3 Chen T-T, Lai M-S, Lin IC, Chung K-P. Exploring and Comparing the Characteristics of Nonlatent and Latent Composite Scores: Implications for Pay-for-Performance Incentive Design. Medical Decision Making. 2012;32(1):132-144. [pmid: 21310853].
4 Kantarevic J, Kralj B. Link between pay for performance incentives and physician payment mechanisms: evidence from the diabetes management incentive in Ontario. Health economics. Dec. 2013;22(12):1417-1439. [pmid: 23203722].
5 Waddimba AC, Meterko M, Beckman HB, Young GJ, Burgess JF Jr. Provider attitudes associated with adherence to evidence-based clinical guidelines in a managed care setting. Medical Care Research & Review. 2010;67(1):93-116. [pmid: 19692552].
6 Baek JD, Xirasagar S, Stoskopf CH, Seidman RL. Physician-targeted financial incentives and primary care physicians' self-reported ability to provide high-quality primary care. Journal of primary care & community health. Jul. 1. 2013;4(3):182-188.
7 Helm C, Holladay CL, Tortorella FR. The performance management system: applying and evaluating a pay-for-performance initiative... including commentary by Candio C. Journal of Healthcare Management. Jan-Feb. 2007. 2007;52(1):49-63. [pmid: 17288117].
8 de Brantes FS, D'Andrea BG. Physicians respond to pay-for-performance incentives: larger incentives yield greater participation. American Journal of Managed Care. 2009;15(5):305-310. [pmid: 19435398].
9 Hadley J, Landon BE, Reschovsky JD. Effects of compensation methods and physician group structure on physicians' perceived incentives to alter services to patients. Health Services Research. 2006;41:1200+. [pmid: 16899003].
10 Hearld LR, Alexander JA, Shi Y, Casalino LP. Pay-for-Performance and Public Reporting Program Participation and Administrative Challenges Among Small- and Medium-Sized Physician Practices. Medical care research and review : MCRR. Jun. 2014;71(3):299-312. [pmid: 24263052].
11 Rodriguez HP, von Glahn T, Elliott MN, Rogers WH, Safran DG. The effect of performance-based financial incentives on improving patient care experiences: a statewide evaluation. Journal of general internal medicine. Dec. 2009;24(12):1281-1288. [pmid: 19826881].
12 Torchiana DF, Colton DG, Rao SK, Lenz SK, Meyer GS, Ferris TG. Massachusetts General Physicians Organization's Quality Incentive Program Produces Encouraging Results. Health Affairs. 2013;32(10):1748-1756. [pmid: 24101064].
13 Young GJ, Beckman H, Baker E. Financial incentives, professional values and performance: A study of pay-for-performance in a professional organization. Journal of Organizational Behavior. 2012;33(7):964-983.
14 Werner RM, Dudley RA. Making the ‘pay’matter in pay-for-performance: implications for payment strategies. Health Affairs. 2009;28(5):1498-1508. [pmid: 19738269].
15 Andriole KP, Prevedello LM, Dufault A, et al. Augmenting the impact of technology adoption with financial incentive to improve radiology report signature times. Journal of the American College of Radiology. 2010;7(3):198-204. [pmid: 20193925].
16 Benzer JK, Young GJ, Burgess JF Jr., et al. Sustainability of quality improvement following removal of pay-for-performance incentives. Journal of general internal medicine. Jan. 2013;29(1):127-132. [pmid: 23929219].
17 Hysong SJ, Khan MM, Petersen LA. Passive monitoring versus active assessment of clinical performance: impact on measured quality of care. Medical care. 2011;49(10):883-890. [pmid: 21918399].
18 Caley M, Burn S, Marshall T, Rouse A. Increasing the QOF upper payment threshold in general practices in England: impact of implementing government proposals. The British journal of general practice : the journal of the Royal College of General Practitioners. Jan. 2014;64(618):e54-59. [pmid: 24567583].
19 Shih T, Nicholas LH, Thumma JR, Birkmeyer JD, Dimick JB. Does pay-for-performance improve surgical outcomes? An evaluation of phase 2 of the Premier Hospital Quality Incentive Demonstration. Annals of surgery. Apr. 2014;259(4):677-681. [pmid: 24368657].
20 Feng Y, Ma A, Farrar S, Sutton M. THE TOUGHER THE BETTER: AN ECONOMIC ANALYSIS OF INCREASED PAYMENT THRESHOLDS ON THE PERFORMANCE OF GENERAL PRACTICES. Health economics. Jan. 5. 2014.
21 Kontopantelis E, Doran T, Gravelle H, Goudie R, Siciliani L, Sutton M. Family Doctor Responses to Changes in Incentives for Influenza Immunization under the U.K. Quality and Outcomes Framework Pay-for-Performance Scheme. Health services research. 2012;47(3 Pt 1):1117-1136. [pmid: 22171997].
22 Kontopantelis E, Springate D, Reeves D, Ashcroft DM, Valderas JM, Doran T. Withdrawing performance indicators: retrospective analysis of general practice performance under UK Quality and Outcomes Framework. BMJ (Clinical research ed.). 2014;348:g330.
23 Arrowsmith ME, Majeed A, Lee JT, Saxena S. Impact of pay for performance on prescribing of long-acting reversible contraception in primary care: an interrupted time series study. PloS one. 2014;9(4):e92205. [pmid: 24694949].
24 Bhattacharyya T, Mehta P, Freiberg AA. Hospital characteristics associated with success in a pay-for-performance program in orthopaedic surgery. Journal of Bone & Joint Surgery, American Volume. 2008;90A(6):1240-1243.
25 Greene J. An examination of pay-for-performance in general practice in Australia. Health services research. Aug. 2013;48(4):1415-1432. [pmid: 23350933].
26 Kirschner K, Braspenning J, Akkermans RP, Jacobs JE, Grol R. Assessment of a pay-for-performance program in primary care designed by target users. Family practice. Apr. 2013;30(2):161-171. [pmid: 22997223].
27 Ashworth M, Armstrong D. The relationship between general practice characteristics and quality of care: a national survey of quality indicators used in the UK Quality and Outcomes Framework, 2004-5. BMC family practice. 2006;7:68. [pmid: 17096861].
28 Ashworth M, Schofield P, Seed P, Durbaba S, Kordowicz M, Jones R. Identifying poorly performing general practices in England: a longitudinal study using data from the quality and outcomes framework. Journal of health services research & policy. Jan. 2011;16(1):21-27. [pmid: 21186318].
29 Walker N, Bankart J, Brunskill N, Baker R. Which factors are associated with higher rates of chronic kidney disease recording in primary care? A cross-sectional survey of GP practices. The British journal of general practice : the journal of the Royal College of General Practitioners. Mar. 2011;61(584):203-205. [pmid: 21375906].
30 Wang Y, O'Donnell CA, Mackay DF, Watt GC. Practice size and quality attainment under the new GMS contract: a cross-sectional analysis. The British journal of general practice : the journal of the Royal College of General Practitioners. Nov. 2006;56(532):830-835. [pmid: 17132349].
31 Miller SC, Looze J, Shield R, et al. Culture change practice in U.S. nursing homes: prevalence and variation by state medicaid reimbursement policies. The Gerontologist. Jun. 2014;54(3):434-445. [pmid: 23514674].
32 Doran T, Campbell S, Fullwood C, Kontopantelis E, Roland M. Performance of small general practices under the UK's Quality and Outcomes Framework. British Journal of General Practice. 2010;60(578):335-344.
33 Morgan CL, Beerstecher HJ. Primary care funding, contract status, and outcomes: an observational study. The British journal of general practice : the journal of the Royal College of General Practitioners. Nov. 2006;56(532):825-829. [pmid: 17132348].
34 Tahrani AA, McCarthy M, Godson J, et al. Impact of practice size on delivery of diabetes care before and after the Quality and Outcomes Framework implementation. The British journal of general practice : the journal of the Royal College of General Practitioners. Aug. 2008;58(553):576-579. [pmid: 18682020].
35 Gemmell I, Campbell S, Hann M, Sibbald B. Assessing workload in general practice in England before and after the introduction of the pay-for-performance contract. Journal of Advanced Nursing. 2009;65(3):509-515. [pmid: 19222648].
36 Begum R, Smith Ryan M, Winther CH, et al. Small practices' experience with EHR, quality measurement, and incentives. The American journal of managed care. Nov. 2013;19(10 Spec No):eSP12-18. [pmid: 24511883].
37 Dalton ARH, Alshamsan R, Majeed A, Millett C. Exclusion of patients from quality measurement of diabetes care in the UK pay-for-performance programme. Diabetic Medicine. 2011;28(5):525-531. [pmid: 21294767].
38 Kruse GR, Chang Y, Kelley JH, Linder JA, Einbinder JS, Rigotti NA. Healthcare system effects of pay-for-performance for smoking status documentation. The American journal of managed care. Jul. 2013;19(7):554-561. [pmid: 23919419].
39 Li J, Hurley J, Decicca P, Buckley G. PHYSICIAN RESPONSE TO PAY-FOR-PERFORMANCE: EVIDENCE FROM A NATURAL EXPERIMENT. Health economics. Jul. 17. 2013.
40 Norbury M, Fawkes N, Guthrie B. Impact of the GP contract on inequalities associated with influenza immunisation: a retrospective population-database analysis. The British journal of general practice : the journal of the Royal College of General Practitioners. Jul. 2011;61(588):e379-385. [pmid: 21722444].
41 Vamos EP, Pape UJ, Bottle A, et al. Association of practice size and pay-for-performance incentives with the quality of diabetes management in primary care. CMAJ: Canadian Medical Association Journal. 2011;183(12):E809-816. [pmid: 21810950].
42 Saint-Lary O, Bernard E, Sicsic J, Plu I, Francois-Purssell I, Franc C. Why did most French GPs choose not to join the voluntary national pay-for-performance program?. PloS one. 2013;8(9):e72684. [pmid: 24039794].
43 Campbell S, Reeves D, Kontopantelis E, Middleton E, Sibbald B, Roland M. Quality of primary care in England with the introduction of pay for performance. New England Journal of Medicine. 2007;357(2):181-190. [pmid: 17625132].
44 Lindenauer PK, Remus D, Roman S, et al. Public reporting and pay for performance in hospital quality improvement. New England Journal of Medicine. 2007;356(5):486-496. [pmid: 17259444].
45 United States Government Accountability Office. VA Health Care. Actions needed to improve administration of the provider performance pay and award systems: Report to congressional requesters. 2013.
46 Kizer KW, Kirsh SR. The double edged sword of performance measurement. Journal of general internal medicine. 2012;27(4):395-397. [pmid: 22271270].
47 Petersen LA, Woodard LD, Urech T, Daw C, Sookanan S. Does pay-for-performance improve the quality of health care?. Annals of internal medicine. 2006;145(4):265-272. [pmid: 16908917].
48 Dudley R, Frolich A, Robinowitz D, Talavera J, Broadhead P, Luft H. Strategies to support quality-based purchasing: A review of the evidence. Prepared by the Stanford-University of California San Francisco Evidence-based Practice Center under Contract No. 290-02-0017. AHRQ Publication No. 04-0057. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
49 Damschroder L, Aron D, Keith R, Kirsh S, Alexander J, Lowery J. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implementation science : IS. 2009;4(50).
50 Pritchard R, Weaver S, Ashwood E. Evidence-based productivity improvement: A practical guide to the Productivity Measurement and Enhancement System (ProMES). New York. Routledge. 2011.
51 Pritchard R, Harrell M, DiazGranados D, Guzman M. The productivity measurement and enhancement system: a meta-analysis. J Appl Psychol. 2008;93(3):540-567. [pmid: 18457486].
52 Damberg CL, Sorbero ME, Mehrotra A, Teleki S, Lovejoy S, Bradley L. An environmental scan of pay for performance in the hospital setting: final report. Washington, DC: Office of the Assistant Secretary for Planning and Evaluation (ASPE). 2007.
53 Treadwell JR, Singh S, Talati R, McPheeters ML, Reston JT. A Framework for“ Best Evidence” Approaches in Systematic Reviews. 2011.
54 Chou R, Helfand M. Challenges in systematic reviews that assess treatment harms. Annals of internal medicine. 2005;142(12_Part_2):1090-1099. [pmid: 15968034].
55 Wells G, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Dec 22, 2014.
56 Mullen KJ, Frank RG, Rosenthal MB. Can you get what you pay for? Pay-for-performance and the quality of healthcare providers. Rand J Econ. 2010;41(1):64-91. [pmid: 21667575].
57 Fagan PJ, Schuster AB, Boyd C, et al. Chronic care improvement in primary care: evaluation of an integrated pay-for-performance and practice-based care coordination program among elderly patients with diabetes. Health services research. 2010;45(6 Pt 1):1763-1782. [pmid: 20849553].
58 Chien AT, Li Z, Rosenthal MB. Improving timely childhood immunizations through pay for performance in Medicaid-managed care. Health services research. 2010;45(6 Pt 2):1934-1947. [pmid: 20849554].
59 Chien AT, Eastman D, Li Z, Rosenthal MB. Impact of a pay for performance program to improve diabetes care in the safety net. Preventive medicine. 2012;55:S80-85. [pmid: 23046985].
60 Pearson SD, Schneider EC, Kleinman KP, Coltin KL, Singer JA. The impact of pay-for-performance on health care quality in Massachusetts, 2001-2003. Health Aff. 2008;27(4):1167-1176.
61 Levin-Scherz J, DeVita N, Timbie J. Impact of pay-for-performance contracts and network registry on diabetes and asthma HEDIS measures in an integrated delivery network. Medical care research and review : MCRR. 2006;63(1 Suppl):14S-28S. [pmid: 16688922].
62 Rosenthal MB, de Brantes FS, Sinaiko AD, Frankel M, Robbins RD, Young S. Bridges to Excellence--recognizing high-quality care: analysis of physician quality and resource use. The American journal of managed care. 2008;14(10):670-677. [pmid: 18837645].
63 Doran T, Kontopantelis E, Valderas JM, et al. Effect of financial incentives on incentivised and non-incentivised clinical activities: longitudinal analysis of data from the UK Quality and Outcomes Framework. BMJ (Clinical research ed.). 2011;342:d3590.
64 Kontopantelis E, Reeves D, Valderas JM, Campbell S, Doran T. Recorded quality of primary care for patients with diabetes in England before and after the introduction of a financial incentive scheme: a longitudinal observational study. BMJ quality & safety. Jan. 2013;22(1):53-64.
65 Simpson CR, Hannaford PC, Ritchie LD, Sheikh A, Williams D. Impact of the pay-for-performance contract and the management of hypertension in Scottish primary care: a 6-year population-based repeated cross-sectional study. British Journal of General Practice. 2011;61(588):443-451.
66 Szatkowski L, McNeill A, Lewis S, Coleman T. A comparison of patient recall of smoking cessation advice with advice recorded in electronic medical records. BMC public health. 2011;11:291. [pmid: 21569283].
67 Calvert M, Shankar A, McManus RJ, Lester H, Freemantle N. Effect of the quality and outcomes framework on diabetes care in the United Kingdom: retrospective cohort study. BMJ (Clinical research ed.). 2009;338:b1870.
68 Karunaratne K, Stevens P, Irving J, et al. The impact of pay for performance on the control of blood pressure in people with chronic kidney disease stage 3-5. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Aug. 2013;28(8):2107-2116.
69 Richards MR, Sindelar JL. Rewarding healthy food choices in SNAP: behavioral economic applications. The Milbank quarterly. Jun. 2013;91(2):395-412. [pmid: 23758515].
70 MacBride-Stewart SP, Elton R, Walley T. Do quality incentives change prescribing patterns in primary care? An observational study in Scotland. Family practice. Feb. 2008;25(1):27-32. [pmid: 18245796].
71 Millett C, Gray J, Saxena S, Netuveli G, Majeed A. Impact of a pay-for-performance incentive on support for smoking cessation and on smoking prevalence among people with diabetes. CMAJ: Canadian Medical Association Journal. 2007;176(12):1705-1710. [pmid: 17548383].
72 Millett C, Bottle A, Ng A, et al. Pay for perfomance and the quality of diabetes management in individuals with and without co-morbid medical conditions. Journal of the Royal Society of Medicine. 2009;102(9):369-377. [pmid: 19734534].
73 Murray J, Saxena S, Millett C, Curcin V, de Lusignan S, Majeed A. Reductions in risk factors for secondary prevention of coronary heart disease by ethnic group in south-west London: 10-year longitudinal study (1998-2007). Family practice. Aug. 2010;27(4):430-438. [pmid: 20538744].
74 Smith CJ, Gribbin J, Challen KB, Hubbard RB. The impact of the 2004 NICE guideline and 2003 General Medical Services contract on COPD in primary care in the UK. QJM : monthly journal of the Association of Physicians. Feb. 2008;101(2):145-153. [pmid: 18180254].
75 Sutton M, Elder R, Guthrie B, Watt G. Record rewards: the effects of targeted quality incentives on the recording of risk factors by primary care providers. Health economics. Jan. 2010;19(1):1-13. [pmid: 19206084].
76 Taggar JS, Coleman T, Lewis S, Szatkowski L. The impact of the Quality and Outcomes Framework (QOF) on the recording of smoking targets in primary care medical records: cross-sectional analyses from The Health Improvement Network (THIN) database. BMC public health. 2012;12:329. [pmid: 22559290].
77 Tahrani AA, McCarthy M, Godson J, et al. Diabetes care and the new GMS contract: the evidence for a whole county. The British journal of general practice : the journal of the Royal College of General Practitioners. Jun. 2007;57(539):483-485. [pmid: 17550674].
78 Cheng SH, Lee TT, Chen CC. A Longitudinal Examination of a Pay-for-Performance Program for Diabetes Care: Evidence From a Natural Experiment. Medical care. 2012;50(2):109-116. [pmid: 22249920].
79 Lai CL, Hou YH. The association of clinical guideline adherence and pay-for-performance among patients with diabetes. Journal of the Chinese Medical Association : JCMA. Feb. 2013;76(2):102-107. [pmid: 23351421].
80 Lee T, Cheng S, Chen C, Lai M. A pay-for-performance program for diabetes care in Taiwan: a preliminary assessment. American Journal of Managed Care. 2010;16(1):65-69. [pmid: 20148607].
81 Tan EC, Pwu RF, Chen DR, Yang MC. Is a diabetes pay-for-performance program cost-effective under the National Health Insurance in Taiwan?. Quality of life research : an international journal of quality of life aspects of treatment, care and rehabilitation. Mar. 2014;23(2):687-696.
82 Chang R-E, Lin S-P, Aron DC. A Pay-For-Performance Program In Taiwan Improved Care For Some Diabetes Patients, But Doctors May Have Excluded Sicker Ones. Health Affairs. 2012;31(1):93-102. [pmid: 22232099].
83 Martens JD, Werkhoven MJ, Severens JL, Winkens RAG. Effects of a behaviour independent financial incentive on prescribing behaviour of general practitioners. Journal of Evaluation in Clinical Practice. 2007;13(3):369-373. [pmid: 17518801].
84 Rat C, Penhouet G, Gaultier A, et al. Did the new French pay-for-performance system modify benzodiazepine prescribing practices?. BMC health services research. 2014:301. [pmid: 25011548].
85 Bhalla R, Schechter CB, Strelnick AH, Deb N, Meissner P, Currie BP. Pay for performance improves quality across demographic groups. Quality management in health care. Jul-Sep. 2013;22(3):199-209. [pmid: 23807132].
86 Esse T, Serna O, Chitnis A, Johnson M, Fernandez N. Quality compensation programs: are they worth all the hype? A comparison of outcomes within a Medicare advantage heart failure population. Journal of managed care pharmacy : JMCP. May. 2013;19(4):317-324. [pmid: 23627577].
87 Friedberg MW, Schneider EC, Rosenthal MB, Volpp KG, Werner RM. Association between participation in a multipayer medical home intervention and changes in quality, utilization, and costs of care. JAMA : the journal of the American Medical Association. Feb. 26. 2014;311(8):815-825. [pmid: 24570245].
88 Pechlivanoglou P, Wieringa JE, de Jager T, Postma MJ. THE EFFECT OF FINANCIAL AND EDUCATIONAL INCENTIVES ON RATIONAL PRESCRIBING. A STATE-SPACE APPROACH. Health economics. Feb. 11. 2014.
89 Kalwij S, French S, Mugezi R, Baraitser P. Using educational outreach and a financial incentive to increase general practices' contribution to chlamydia screening in South-East London 2003-2011. BMC public health. 2012;12:802-802. [pmid: 22984897].
90 Glickman SW, Ou F, DeLong ER, et al. Pay for performance, quality of care, and outcomes in acute myocardial infarction. JAMA: Journal of the American Medical Association. 2007;297(21):2373-2380. [pmid: 17551130].
91 Werner RM, Kolstad JT, Stuart EA, Polsky D. The Effect Of Pay-For-Performance In Hospitals: Lessons For Quality Improvement. Health Affairs. 2011;30(4):690-698. [pmid: 21471490].
92 Ryan AM, Blustein J, Doran T, Michelow MD, Casalino LP. The effect of Phase 2 of the Premier Hospital Quality Incentive Demonstration on incentive payments to hospitals caring for disadvantaged patients. Health services research. 2012;47(4):1418-1436. [pmid: 22417137].
93 Ryan AM, Blustein J. The effect of the MassHealth hospital pay-for-performance program on quality. Health services research. 2011;46(3):712-728. [pmid: 21210796].
94 Ryan A, Sutton M, Doran T. Does winning a pay-for-performance bonus improve subsequent quality performance? Evidence from the Hospital Quality Incentive Demonstration. Health services research. Apr. 2014;49(2):568-587. [pmid: 23909992].
95 Ryan AM, Burgess JF, Pesko MF, Borden WB, Dimick JB. The early effects of medicare's mandatory hospital pay-for-performance program. Health services research. 2014.
96 Colais P, Pinnarelli L, Fusco D, Davoli M, Braga M, Perucci CA. The impact of a pay-for-performance system on timing to hip fracture surgery: experience from the Lazio Region (Italy). BMC health services research. 2013;13:393. [pmid: 24099264].
97 Kuo RNC, Kuo-Piao C, Mei-Shu L. Effect of the Pay-for-Performance Program for Breast Cancer Care in Taiwan. Journal of Oncology Practice. 2011:e8s-e15s. [pmid: 21886513].
98 Li YH, Tsai WC, Khan M, et al. The effects of pay-for-performance on tuberculosis treatment in Taiwan. Health Policy & Planning. 2010;25(4):334-341. [pmid: 20207703].
99 Kanwar M, Brar N, Khatib R, Fakih M. Misdiagnosis of community-acquired pneumonia and inappropriate utilization of antibiotics: side effects of the 4-h antibiotic administration rule. Chest. 2007;131(6):1865-1869. [pmid: 17400668].
100 Kristensen SR, Meacock R, Turner AJ, et al. Long-Term Effect of Hospital Pay for Performance on Mortality in England. The New England journal of medicine. August. 7. 2014. 2014;371:540-548. [pmid: 25099578].
101 Sidorenkov G, Haaijer-Ruskamp FM, de Zeeuw D, Bilo H, Denig P. Review: relation between quality-of-care indicators for diabetes and patient outcomes: a systematic literature review. Medical care research and review : MCRR. 2011;68(3):263-289. [pmid: 21536606].
102 Rosenthal MB, Li Z, Robertson AD, Milstein A. Impact of financial incentives for prenatal care on birth outcomes and spending. Health services research. 2009;44(5 Pt 1):1465-1479. [pmid: 19619248].
103 Ryan AM, Doran T. The Effect of Improving Processes of Care on Patient Outcomes: Evidence From the United Kingdom's Quality and Outcomes Framework. Medical care. 2012;50(3):191-199. [pmid: 22329994].
104 Alshamsan R, Lee JT, Majeed A, Netuveli G, Millett C. Effect of a UK Pay-for-Performance Program on Ethnic Disparities in Diabetes Outcomes: Interrupted Time Series Analysis. Annals of family medicine. 2012;10(3):228-234. [pmid: 22585887].
105 Vaghela P, Ashworth M, Schofield P, Gulliford MC. Population Intermediate Outcomes of Diabetes Under Pay-for-Performance Incentives in England From 2004 to 2008. Diabetes Care. 2009;32(3):427-429. [pmid: 19106379].
106 Share DA, Mason MH. Michigan's Physician Group Incentive Program Offers A Regional Model For Incremental Tee For Value' Payment Reform. Health Affairs. 2012;31(9):1993-2001. [pmid: 22949448].
107 Chen CS, Liu TC, Chen B, Lin CL. The failure of financial incentive? The seemingly inexorable rise of cesarean section. Social science & medicine (1982). Jan. 2014;101:47-51. [pmid: 24560223].
108 Krumholz HM, Lin Z, Keenan PS, et al. Relationship between hospital readmission and mortality rates for patients hospitalized with acute myocardial infarction, heart failure, or pneumonia. JAMA : the journal of the American Medical Association. 2013;309(6):587-593. [pmid: 23403683].
109 Nicholas LH, Osborne NH, Birkmeyer JD, Dimick JB. Hospital process compliance and surgical outcomes in medicare beneficiaries. Arch Surg. 2010;145(10):999-1004. [pmid: 20956770].
110 Werner RM, Bradlow ET. Relationship between Medicare's hospital compare performance measures and mortality rates. JAMA : the journal of the American Medical Association. 2006;296(22):2694-2702. [pmid: 17164455].
111 Ryan A. Effects of the Premier Hospital Quality Incentive Demonstration on Medicare patient mortality and cost. Health services research. 2009;44(3):821-842. [pmid: 19674427].
112 Sutton M, Nikolova S, Boaden R, Lester H, McDonald R, Roland M. Reduced mortality with hospital pay for performance in England. New England Journal of Medicine. 2012;367(19):1821-1828. [pmid: 23134382].
113 Ryan RM, Deci EL. Self-determination theory and the facilitation of intrinsic motivation, social development, and well-being. American Psychologist. 2000;55:68-78. [pmid: 11392867].
114 Kerr EA, Lucatorto MA, Holleman R, Hogan MM, Klamerus ML, Hofer TP. Monitoring performance for blood pressure management among patients with diabetes mellitus: too much of a good thing?. Arch Intern Med. 2012;172(12):938-945. [pmid: 22641246].
115 Doran T, Fullwood C, Kontopantelis E, Reeves D. Effect of financial incentives on inequalities in the delivery of primary clinical care in England: analysis of clinical activity indicators for the quality and outcomes framework. Lancet. Aug. 30. 2008;372(9640):728-736. [pmid: 18701159].
116 Chien AT, Wroblewski K, Damberg C, et al. Do physician organizations located in lower socioeconomic status areas score lower on pay-for-performance measures?. JGIM: Journal of General Internal Medicine. 2012;27(5):548-554. [pmid: 22160817].
117 Lee JT, Netuveli G, Majeed A, Millett C. The effects of pay for performance on disparities in stroke, hypertension, and coronary heart disease management: interrupted time series study. PloS one. 2011;6(12):e27236. [pmid: 22194781].
118 Schofield P, Saka O, Ashworth M. Ethnic differences in blood pressure monitoring and control in south east London. The British journal of general practice : the journal of the Royal College of General Practitioners. Apr. 2011;61(585):190-196. [pmid: 21439177].
119 Millett C, Netuveli G, Saxena S, Majeed A. Impact of pay for performance on ethnic disparities in intermediate outcomes for diabetes: a longitudinal study. Diabetes Care. 2009;32(3):404-409. [pmid: 19073759].
120 Hamilton FL, Laverty AA, Vamos EP, Majeed A, Millett C. Effect of financial incentives on ethnic disparities in smoking cessation interventions in primary care: cross-sectional study. Journal of public health (Oxford, England). Mar. 2013;35(1):75-84.
121 Addink RW, Bankart MJ, Murtagh GM, Baker R. Limited impact on patient experience of access of a pay for performance scheme in England in the first year. European Journal of General Practice. 2011;17(2):81-86. [pmid: 21303230].
122 Ashworth M, Medina J, Morgan M. Effect of social deprivation on blood pressure monitoring and control in England: a survey of data from the quality and outcomes framework. BMJ (Clinical research ed.). 2008;337:a2030.
123 Crawley D, Ng A, Mainous AG III, Majeed A, Millett C. Impact of pay for performance on quality of chronic disease management by social class group in England. Journal of the Royal Society of Medicine. 2009;102(3):103-107. [pmid: 19297651].
124 Dixon A, Khachatryan A, Gilmour S. Does general practice reduce health inequalities? Analysis of quality and outcomes framework data. European journal of public health. Feb. 2012;22(1):9-13. [pmid: 21148179].
125 Hamilton FL, Bottle A, Vamos EP, et al. Impact of a pay-for-performance incentive scheme on age, sex, and socioeconomic disparities in diabetes management in UK primary care. Journal of Ambulatory Care Management. 2010;33(4):336-349. [pmid: 20838113].
126 McLean G, Sutton M, Guthrie B. Deprivation and quality of primary care services: evidence for persistence of the inverse care law from the UK Quality and Outcomes Framework. Journal of epidemiology and community health. Nov. 2006;60(11):917-922. [pmid: 17053278].
127 Downing A, Rudge G, Cheng Y, Tu YK, Keen J, Gilthorpe MS. Do the UK government's new Quality and Outcomes Framework (QOF) scores adequately measure primary care performance? A cross-sectional survey of routine healthcare data. BMC health services research. 2007;7:166. [pmid: 17941984].
128 Chen TT, Chung KP, Lin IC, Lai MS. The unintended consequence of diabetes mellitus pay-for-performance (P4P) program in Taiwan: are patients with more comorbidities or more severe conditions likely to be excluded from the P4P program?. Health services research. 2011;46(1 Pt 1):47-60. [pmid: 20880044].
129 Carey IM, Nightingale CM, DeWilde S, Harris T, Whincup PH, Cook DG. Blood pressure recording bias during a period when the Quality and Outcomes Framework was introduced. Journal of human hypertension. Nov. 2009;23(11):764-770. [pmid: 19279657].
130 Hardy B, Szatkowski L, Tata LJ, Coleman T, Dhalwani NN. Smoking cessation advice recorded during pregnancy in United Kingdom primary care. BMC family practice. 2014;15:21. [pmid: 24484239].
131 Dhalwani NN, Tata LJ, Coleman T, Fleming KM, Szatkowski L. Completeness of maternal smoking status recording during pregnancy in United Kingdom primary care data. PloS one. 2013;8(9):e72218. [pmid: 24069143].
132 Fernandez Urrusuno R, Perez Perez P, Montero Balosa MC, Marquez Calzada C, Pascual de la Pisa B. Compliance with quality prescribing indicators linked to financial incentives: what about not incentivized indicators?: an observational study. European journal of clinical pharmacology. Mar. 2014;70(3):303-311. [pmid: 24297343].
133 Chien AT, Chin MH, Davis AM, Casalino LP. Pay for performance, public reporting, and racial disparities in health care: how are programs being designed?. Medical Care Research & Review. 2007;64(5):283S-304. [pmid: 17881629].