# METHODS

## TOPIC DEVELOPMENT

This topic was submitted to the ESP Coordinating Center for development by David Atkins, MD, MPH, Director, Health Services Research and Development in collaboration with Joe Francis, MD, Director, Clinical Analytics and Reporting and Carolyn Clancy, MD, Interim Under Secretary for Health. We also received input from a Technical Expert Panel (TEP; see Appendix A).

The Key Questions, which were developed in concert with the stakeholders, are as follows:

KQ 1 What are the effects of pay for performance programs on patient outcomes and processes of care?
KQ 2 What implementation factors modify the effectiveness of pay for performance?
KQ 3 What are the positive and negative unintended consequences, including any effect on health disparities, associated with pay for performance?

Criteria for population, interventions, comparators, outcomes, timing, and setting were developed in collaboration with our stakeholders and TEP (see Appendix B).

A report on Value-Based Purchasing (VBP) programs conducted by Damberg and colleagues at the RAND Corporation, and commissioned by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) in the Department of Health and Human Services (HHS) was released during the writing of this report.1 The RAND report examined 3 VBP models: pay for performance (P4P), accountable care organization (ACO), and bundled payments. Our report examines only P4P, focuses on large health organizations and other systems similar to the VHA, and includes a summary of the findings related to P4P from the RAND report written in collaboration with the primary author.

## SEARCH STRATEGY

We based our search on 2 of the P4P search strategies performed for the RAND report,1 and searched PubMed, PsycINFO (Ovid), and CINAHL (EBSCO) for studies published between December 1, 2012 and April 30, 2014 for the primary search, and between June 1, 2007 to April 30, 2014 for the secondary. Our search was limited to peer-reviewed articles involving human subjects published in English language that were not included in either of the previous RAND reports.1,52 We also conducted a grey literature search of Business Economics and Theory (Gale), Business Source Elite (EBSCO), Scopus, Faculty of 1000, Gartner Research, and websites for the RAND Corporation, the Agency for Healthcare Research And Quality (AHRQ), Health Services Research in Progress, Kaiser Permanente's Center for Health Research, Quest for Quality and Improved Performance (QQUIP), the Campbell Collaboration, National Institute for Health and Care Excellence (NICE), Medical Research Institute, and NIH Reporter. We performed targeted searches of PubMed and Google for the following programs: Quality and Outcomes Framework (QOF), Centers for Medicare and Medicaid Services (CMS) Premier Hospital Quality Initiative Demonstration Project (HQID), CMS Hospital Value Based Purchasing Program, CMS Physician Group Practice Demonstration, Hawaii Medical Service Association (HMSA) P4P Program, Integrated Health Association's California Pay for Performance Program, Blue Cross Blue Shield of Massachusetts Alternative Quality Contract, and the Massachusetts Medicaid Hospital Based (MassHealth) P4P Program. The search strategy is reported in Appendix C. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts. All citations were imported into an electronic database (EndNote X4).

## STUDY SELECTION

Five investigators trained in the critical analysis of literature independently reviewed titles and abstracts identified from literature searches for relevance to the Key Questions. Two investigators independently assessed each study for inclusion based on the criteria provided in Appendix D. We used a “best evidence” approach to guide study design criteria depending on the question under consideration and the literature available.53 We included direct pay for performance programs targeting healthcare providers at the individual, group, managerial, or institutional level. We excluded studies examining patient-targeted financial incentives, as well as payment models other than direct pay for performance, such as managed care, capitation, bundled payments, and accountable care organizations. Only studies examining systems and patient populations similar to the VHA were included, thus we excluded studies conducted in countries with healthcare systems that differ widely from US or VHA settings (eg, Africa, Philippines), studies that were not conducted in hospital or ambulatory settings (eg, nursing homes), and studies with child patient populations. To assess patient and process outcomes, but not implementation characteristics or unintended consequences, we included only studies with patient populations of greater than 10,000, and studies with a comparison group or longitudinal studies with 3 or more time points reporting trends. Studies with smaller patient samples and pre-post study designs were included to assess implementation characteristics and harms/unintended consequences.54

## DATA ABSTRACTION

We abstracted data from each included study on study design; sample size; country; relevance to the VHA; program description; incentive structure; target of the incentive (eg, provider, management, administration); comparator; outcome measures; and results. Tables 3-15 report these data. Data were abstracted by one investigator, and reviewed for accuracy by at least one additional investigator.

## QUALITY ASSESSMENT

We assessed the quality of included studies pertaining to all 3 Key Questions. Due to the variation in study designs and large number of observational studies, we used the Newcastle-Ottawa Quality Assessment Scale to appraise study quality.55 Data related to risk of bias were abstracted by one investigator, and reviewed for accuracy by at least one additional investigator.

## DATA SYNTHESIS AND ANALYSIS

We qualitatively synthesized the results of included studies. Due to the large number of observational trials and heterogeneity among the studies, meta-analysis was not performed. We constructed evidence tables outlining study characteristics and results, organized by key question, and analyzed individual and program-related study findings to draw conclusions.

## SUMMARY OF RAND'S FINDINGS ON PAY FOR PERFORMANCE PROGRAMS

In March 2014, the RAND Corporation released a review examining Value-Based Purchasing, a component of which examined P4P programs.1 RAND's review was conducted for the US Department of Health and Human Services and comprehensively examines research related to P4P, particularly in the United States. The RAND report included a total of 103 studies, 48 of which examined ambulatory programs, and 38 examining P4P programs in hospital settings. In collaboration with the primary author, we summarized RAND's findings related to studies examining P4P programs in populations and settings similar to the VHA. Damberg and others at RAND found that many of the P4P evaluations they examined suffered from methodological problems or represented very short-term tests of P4P, and these studies tended to show positive effects as compared to studies that had strong study designs and were of longer duration. Due to the heterogeneous nature of the studies and programs, synthesizing evidence across studies presented a challenge, as the studies also used different variables of interest, study periods, incentive structure, and analysis designs. In addition, some of the studies were poorly described, making it difficult to understand key aspects of the study, such as the methods used and the duration of the intervention. For the purpose of this report, we limit our summary of RAND's report to the findings from methodologically strong studies of sustained P4P experiments in ambulatory and hospital settings, examining the effects on (1) clinical quality, (2) health outcomes, and (3) unintended effects (including disparities in care). These studies tended to have multiple years of data, focused on large ongoing national or regional efforts, and used methodologies such as difference-in-differences or instrumental variable models to address confounding that might result from unobserved variable bias. See Appendix E for a list of summarized studies.

## DISCUSSIONS WITH KEY INFORMANTS

We engaged experienced P4P researchers as key informants (KI) to gain insight into issues related to implementation and unintended consequences (Key Questions 2 and 3). Key informants were identified as having expertise on pay for performance programs in healthcare through a review of relevant literature, and through consultation with our stakeholders and Technical Expert Panel. We developed a general semi-structured discussion guide addressing implementation, unintended consequences, health disparities, recommendations for the improvement of P4P programs, future research needs, and applicability to the VHA (see Appendix F), which was approved and determined to be exempt by the VA Portland Health Care System's (VAPORHCS) Institutional Review Board. We invited 45 individuals, of which 14 agreed to participate (see Appendix G for a list of key informants).

Key informant interviews were conducted via telephone, and lasted an average of 60 minutes. A minimum of 2 investigators were present, with one investigator dedicated to taking notes. One call was recorded and transcribed at the request of the KI. We individually customized the discussion guide for each participant, and provided the guide prior to the scheduled call.

Five investigators conducted independent inductive open-coding of interview notes. One investigator with qualitative research experience (KK) reviewed investigators' codes and identified common themes.