# ACKNOWLEDGMENTS

The authors would like to thank the Key Informants and Technical Expert Panel for their participation and valued input. In particular we would also like to recognize and thank Laura Damschroder, MS, MPH for her contribution the conceptual framework used in this review.