# CONCEPTUAL FRAMEWORK

Through an examination of previous conceptual frameworks of financial incentives (see Dudley et al 2004 and Damberg et al 2014), and in consultation with our Technical Expert Panel (TEP), we developed a framework from which to examine P4P.1,48 Our framework is based primarily on the framework developed by Damberg and others; however, we modified it to focus on the relationship between contextual and local implementation features as described by the Consolidated Framework for Implementation Research (CFIR), and providers' cognitive/affective responses and behaviors (see Figure 1).49

Figure 1 Technical Expert Panel Framework

Central to the framework are:

- Program design features – properties of the intervention itself such as the type of quality measure used or the size of the financial incentive.
- Implementation factors – the following factors are hypothesized to be high-priority constructs influencing P4P outcomes:
  ○ Implementation Processes – actions taken to implement the P4P program such as planning, stakeholder engagement, academic detailing, audit and feedback, and whether the incentive was targeted at the team or individual level.
  ○ Outer Setting – refers to the broader health system context within which an intervention is implemented; the cultural and social norms at the state and federal level; and characteristics of the patient population.
  ○ Inner Setting – refers to characteristics of the institution or organization itself. Examples include institutional goals and priorities, information technology capabilities, learning climate, leadership engagement, and support available for implementation of programs.
  ○ Characteristics of providers.
- Provider cognitive and behavioral responses – refers to provider beliefs and attitudes. Includes cognitive response constructs such as biases, professionalism, heuristics, identification with one's organization. Also includes behavioral response constructs such as risk selection, gaming, systems improvement responses.
- Outcomes – includes process of care outcomes such as performance of recommended screening or disease monitoring, as well as patient outcomes such as achieving target disease management goals (eg, blood pressure, cholesterol levels) and health outcomes.

We conceive provider responses from the perspective of a motivational model that describes a reinforcing cycle of constructs (ie, actions, results, evaluations, outcomes, need satisfaction) which create a negative or positive reinforcing cycle to encourage more or less of a chosen action, depending on how each construct is linked to the next.50,51 P4P is a strong driver, and can strengthen positive or entrench negative behaviors, depending on what happens to reinforce or weaken (positively or negatively) the [underlined: linkages] between each “event” in the chain above. See Table 1 for 2 extreme examples of possible responses that serve to highlight how the same financial incentive intervention may play out in different contexts.

Table 1 Examples of Possible Responses

| “Improvement” Context | “Treat to the Numbers” Context
Actions
Reinforcing linkages between Actions and Results | Background: HbA1c target “relaxed” to 9 to provide the latitude needed to personalize HbA1c goals between 7-9, as specified by VA treatment guidelines. An analysis of patients with uncontrolled glycemia reveals that many patients who should be on insulin are not. Talking with providers reveal that many are hesitant about starting patients on insulin because their patients resist and they are unsure when to start. Better guidance on when and how to start patients on insulin is provided and support by others is provided eg, clinical pharmacist. Positive reinforcing linkage between Action and Results: Provider is given actionable feedback report that lists patients who are candidates for starting on insulin based on criteria developed by a colleague physician. The provider appreciates this information and writes a treatment plan to start a patient on insulin. | Background: Clinical reminder pops up during an encounter with a patient indicating uncontrolled HbA1c at 7.5 instead of the performance target of 7. Provider is concerned that increasing meds will lead to potential harm and patient does not want to take more medications. Negative reinforcing linkage between Action and Results: At first, the provider follows medical judgment (things are not always black and white) even when it does not meet the clinical reminder target and makes no changes in medication. Provider receives “bad boy” letter with this patient listed along with other patients who did not make administrative target of 7. …after receiving multiple letters, eventually bows under pressure from the “dashboard cowboys” who monitor progress toward performance targets and starts to more aggressively intensify medication for this patient and others
Results
Reinforcing linkages between Results and Evaluations | Feedback reports of candidate patients who have been started on insulin show trends over time. Also, receives feedback on the HbA1c performance measure. | Provider is pretty sure s/he made the best medical decision when not intensifying medications but reports indicate performance targets were not being met. Provider feels ill-equipped to address supposed “fall out” patients.
Evaluations
Reinforcing linkages between Evaluations and Outcomes/Need Satisfaction | Provider sees that his/her panel of patients are under better control. Performance targets are met as a result of this clinical improvement initiative. [underlined: Bonuses] are received though linkage of this particular initiative's contribution is unclear because of delays in disbursement and complex and poorly understood criteria. Nonetheless, provider feels satisfaction in job, engaged with organizational goals, and looks for other opportunities to improve clinical care. | Providers say, “we are doing A work, but feel like a failure.” It is unclear how bonuses are tied to meeting the HbA1c target versus many other criteria used to determine bonuses; this disconnect is exacerbated by receiving bonuses months later with no apparent connection with actual work done. Feeling increasingly disengaged and distrustful of non-clinician administrators who “own” performance measures and targets, and as pressure increases to make performance targets that seem at odds with patient needs → creates a “high-stakes” environment which may lead to gaming.