# BACKGROUND

Pay for performance (P4P) refers to the use of financial incentives to stimulate improvements in health care efficiency and quality. P4P belongs to a collection of financing schemes known as alternative payment models (APMs), which are designed to replace fee-for-service (FFS) payment. Whereas FFS payment rewards volume of services, APMs are designed to incentivize better outcomes and value. This is typically achieved through making providers and systems financially vested in patient health status and efficient care delivery. In addition to P4P, other prominent models include bundled payments and medical homes. Although P4P had previously been implemented by private payers on a small scale, there has been an increase in large-scale ambulatory and hospital P4P programs over the last decade in the United States and internationally.

In the early 1990s, the Robert Wood Johnson Foundation funded Rewarding Results, which provided funding to evaluate several large-scale, sustained P4P demonstrations in a handful of markets, including California, Massachusetts, and Rochester, New York. Unfortunately, these evaluations suffered from the lack of a control group, which made it difficult to distinguish P4P effects from those of concurrently implemented initiatives (eg, public reporting of results, use of registries and other electronic monitoring tools).

More recently, the United Kingdom (UK), implemented the Quality Outcomes Framework (QOF), a large-scale ambulatory P4P program which was universally applied to all UK family practices starting in 2004. The QOF was implemented in a single-payer system, with universal electronic medical records (EMRs), and offered large incentives (eg, 35% bonus in addition to a large salary increase). From an evaluation perspective, one of the strengths of the QOF program is the availability of performance data over an extended period prior to the launch of their P4P program, which has allowed evaluators to compare outcome trends before and after the implementation of the P4P program.43 In addition, in the decade since the QOF was introduced the program has undergone a number of changes, including the addition of new measures and removal of others, changes to overall payment size/potential and to minimum and maximum payment thresholds (minimum thresholds are the minimum percentage of targeted patients achieving a measure required to earn an incentive, with maximum thresholds as the required percentage of targeted patients achieving a measure necessary to earn the maximum incentive). A large body of evidence has accumulated, examining not only the effectiveness of the program on targeted measures, but also comparing the effectiveness by socioeconomic status (ie, deprivation), examining issues related to gaming associated with exception reporting (identifying and not being penalized for patients for whom a measure may not apply under certain circumstances such as contraindications or failure to attend a review), and evaluating factors such as the impact of changes to incentivized measures and thresholds, differences in provider group size, and provider characteristics.

In the US, the Centers for Medicare and Medicaid Services (CMS) implemented the Premier Hospital Quality Incentive Demonstration (HQID) in hospital settings and the Physician Group Practice (PGP) demonstration in group practice settings. In both cases, participation was voluntary rather than universally implemented. Of note, CMS began to publicly report the performance of all Inpatient Prospective Payment System hospitals around the time these P4P initiatives began.44

The VHA instituted its performance pay program in 2004 after passage of the VA Heath Care Personnel Enhancement Act. The amount of performance pay awarded to each provider is determined by the degree to which they achieve a set of performance goals which may include measures of care processes (eg, ordering periodic hemoglobin A1c tests in diabetic patients), health outcomes, or fulfillment of work responsibilities (eg, timely completion of training activities). There is also a managerial performance pay program for administrators. The VHA performance pay program allows medical centers and regional networks autonomy in determining the choice of measures that comprise the performance goals for different types of providers. In 2011, approximately 80 percent of VA providers received performance pay at an average of $8,049 per provider.45

In recent years, there have been an increasing number of studies examining the effects of these large-scale and other P4P programs. As experience with and evidence examining these programs have increased, there have been questions raised about the effectiveness of such programs and concerns voiced about the potential for negative unintended consequences.46,47 However, financial incentives programs are complex interventions and vary widely in their implementation, including characteristics of the measures chosen, such as the number of measures incentivized, the type of measure (eg, structural, cost/efficiency, clinical processes, patient/intermediate outcomes, patient experience, etc), as well as features related the incentive structure, such as who the incentive targets (eg, providers, groups, managers, administration), amount, and whether incentives are in the form of rewards (eg, fee differentials, bonuses) or penalties (eg, withholds, repayments to payers), and the frequency of the incentive. Added to the complexity are differences in the contexts in which they are implemented, such as the type of setting (eg, ambulatory settings, hospitals, nursing home, etc), the organizational culture within the setting, and other factors such as patient population. The positive and negative effects associated with any given P4P program likely depends in part on the combination of all of these factors.

The goal of this evidence report is to summarize current evidence examining the effectiveness of financial incentive schemes on processes of care and patient outcomes, as well as the intervention and implementation factors associated with benefits and harms, notably within the VHA and similar large health organizations. A better understanding of the impact of pay for performance schemes aimed at individual providers, managerial staff, and medical practices will guide the VHA in modifying P4P programs to maximize potential benefits and minimize harms.