# KEY INFORMANTS

- Howard Beckman, MD, FACP, FAACH
  CMO, Focused Medical Analytics
  Clinical Professor of Medicine, Family
  Medicine and Public Health Sciences
  University of Rochester School of Medicine and Dentistry
- Justin Benzer, PhD
  Research Health Scientist & Research
  Assistant Professor, Center for Healthcare
  Organization and Implementation Research
  VA Boston Healthcare System & Boston University
- Sule Calikoglu, PhD
  Maryland Health Services Cost Review Commission
- Alyna T. Chien, MD, MS
  Harvard Medical School
  Boston Children's Hospital
- Tim Doran, BSc, MBChB, MPH, MD, MFPH
  Professor of Health Policy, University of York
- Peter J. Fagan, PhD, MDiv.
  Associate Professor of Medical Psychology
  Johns Hopkins University School of Medicine
- Rachel Foskett-Tharby, PhD, MSc, BSc, RGN
  Research Fellow
  University of Birmingham
- Eve A. Kerr, MD, MPH
  Director, VA Center for Clinical Management Research
- Lauren Hersch Nicholas, PhD, MPP
  Johns Hopkins Bloomberg School of Public Health & School of Medicine, Department of Health Policy & Management and Department of Surgery
- Armando Henrique Norman, MD
  Department of Anthropology
  Durham University
- Laura A. Petersen, MD, MPH, FACP
  MEDVAMC Associate Chief of Staff, Research
  Director, VA HSR&D Center for Innovations in Quality, Effectiveness & Safety (IQuESt)
- Martin Roland, CBE, DM, FMedSci
  RAND Professor of Health Services Research, Institute of Public Health
  University of Cambridge School of Clinical Medicine
- Andrew M Ryan, PhD
  Division of Outcomes and Effectiveness Research
  Weill Cornell Medical College
- Rachel Werner, MD, PhD
  Center for Health Equity Research and Promotion
  Philadelphia VAMC
  Associate professor of Medicine
  University of Pennsylvania