# KEY INFORMANT DISCUSSION GUIDE, TEMPLATE

## Portland Evidence-based Synthesis Program

________________________________________________________________________

Understanding the intervention and implementation factors associated with benefits and harms of pay for performance programs in healthcare

Dr. <KEY INFORMANT>

<MONTH, DAY, 2014: TIME PT/ ET>

Conference call: 1.800.767.1750, Access Code: 39528#

1. According to your study, financial incentives had XXX effect on XXXX. What were some of the main factors that contributed to your results?
  a. Probe: Intervention variables such as:
    i. Rewards vs penalties
    ii. Type/nature
    iii. Relative vs absolute performance measures
    iv. Frequency and duration
    v. Certainty of the incentive
  b. Probe: Implementation factors such as:
    i. Inner setting (structural, political, cultural contexts)
    ii. Outer setting (economic, political, social contexts)
    iii. Individuals involved (cultural, organizational, professional, and individual mindsets, norms, interests, affiliations)
    iv. Implementation processes (interaction of related processes within the organization)
2. What did you find were some of the unintended consequences related to financial incentives?
  a. Probe: Positive
    i. Spillover effects
  b. Probe: Negative
    i. Risk selection
    ii. Deterioration of un-incentivized care
    iii. Impairment of intrinsic motivation/professionalism
    iv. Gaming
3. Did you find that financial incentives had any effect on health disparities?
  a. Probe: Were there certain groups that were at a greater disadvantage?
    i. Low income
    ii. Racial/ethnic minority populations
  b. Probe: Why?
    i. Access
    ii. Language barriers
    iii. Lack of insurance/ability to pay
    iv. Etc.
4. What were some of the things that were the most surprising to you?
5. What would you have done differently?