# STUDIES SUMMARIZED IN DAMBERG, 2014^1^

1 Campbell S, Reeves D, Kontopantelis E, Middleton E, Sibbald B, Roland M. Quality of primary care in England with the introduction of pay for performance. New England Journal of Medicine. 2007;357(2):181-190. [pmid: 17625132].
2 Chien AT, Li Z, Rosenthal MB. Improving timely childhood immunizations through pay for performance in Medicaid-managed care. Health Services Research. Dec. 2010;45(6 Pt 2):1934-1947. [pmid: 20849554].
3 Chien AT, Eastman D, Li Z, Rosenthal MB. Impact of a pay for performance program to improve diabetes care in the safety net. Preventive Medicine. Nov. 55 Suppl. 2012:S80-S85. [pmid: 23046985].
4 Christianson J, Leatherman S, Sutherland K. Lessons from evaluations of purchaser pay-for-performance programs: A review of the evidence. Medical Care Research and Review. 2008;65(6 Suppl):5S-35. [pmid: 19015377].
5 Fagan PJ, Schuster AB, Boyd C, Marsteller JA, Griswold M, Murphy SM, Dunbar L, Forrest CB. Chronic care improvement in primary care: Evaluation of an integrated payfor-performance and practice-based care coordination program among elderly patients with diabetes. Health Services Research. Dec. 2010;45(6 Pt 1):1763-1782. [pmid: 20849553].
6 Glickman SW, Ou FS, DeLong ER, Roe MT, Lytle BL, Mulgund J, Rumsfeld JS, Gibler WB, Ohman EM, Schulman KA, Peterson ED. Pay for performance, quality of care, and outcomes in acute myocardial infarction. JAMA. Jun. 6. 2007;297(21):2373-2380. [pmid: 17551130].
7 Krumholz H, Lin Z, Keenan P, Chen J, Ross J, Drye E, Bernheim S, Wang Y, Bradley E, Han L, Normand S. Relationship between hospital readmission and mortality rates for patients hospitalized with acute myocardial infarction, heart failure, or pneumonia. JAMA. 2013;309(6):587-593. [pmid: 23403683].
8 Levin-Scherz J, DeVita N, Timbie J. Impact of pay-for-performance contracts and network registry on diabetes and asthma HEDIS measures in an integrated delivery network. Medical Care Research and Review. Feb. 2006;63(1 Suppl):14S-28S. [pmid: 16688922].
9 Lindenauer PK, Remus D, Roman S, Rothberg MB, Benjamin EM, Ma A, Bratzler DW. Public reporting and pay for performance in hospital quality improvement. New England Journal of Medicine. 2007;356(5):486-496. [pmid: 17259444].
10 Mullen KJ, Frank RG, Rosenthal MB. Can you get what you pay for? Pay-for performance and the quality of healthcare providers. Rand Journal of Economics. Spring. 2010;41(1):64-91. [pmid: 21667575].
11 Nicholas LH, Osborne NH, Birkmeyer JD, Dimick JB. Hospital process compliance and surgical outcomes in medicare beneficiaries. Archives of Surgery. Oct. 2010;145(10):999-1004. [pmid: 20956770].
12 Pearson SD, Schneider EC, Kleinman KP, Coltin KL, Singer JA. The impact of pay-forperformance on health care quality in Massachusetts, 2001–2003. Health Affairs. Jul–Aug. 2008;27(4):1167-1176. [pmid: 18607052].
13 Petersen LA, Woodard LD, Urech T, Daw C, Sookanan S. Does pay-for-performance improve the quality of health care?. Annals of Internal Medicine. Aug. 15. 2006;145(4):265-272. [pmid: 16908917].
14 Rosenthal MB, Li Z, Robertson AD, Milstein A. Impact of financial incentives for prenatal care on birth outcomes and spending. Health Services Research. Oct. 2009;44(5 Pt 1):1465-1479. [pmid: 19619248].
15 Ryan A. Effects of the Premier Hospital Quality Incentive Demonstration on Medicare patient mortality and cost. Health services research. 2009;44(3):821-842. [pmid: 19674427].
16 Ryan AM, Blustein J. The effect of the MassHealth hospital pay-for-performance program on quality. Health services research. 2011;46(3):712-728. [pmid: 21210796].
17 Ryan AM, Doran T. The effect of improving processes of care on patient outcomes: Evidence from the United Kingdom's quality and outcomes framework. Medical care. Mar. 2012;50(3):191-199. [pmid: 22329994].
18 Ryan AM, Blustein J, Doran T, Michelow MD, Casalino LP. The effect of Phase 2 of the Premier Hospital Quality Incentive Demonstration on incentive payments to hospitals caring for disadvantaged patients. Health Services Research. Aug. 2012;47(4):1418-1436. [pmid: 22417137].
19 Sidorenkov G, Haaijer-Ruskamp FM, de Zeeuw D, Bilo H, Denig P. Review: Relation between quality-of-care indicators for diabetes and patient outcomes: A systematic literature review. Medical Care Research and Review. Jun. 2011;68(3):263-289. [pmid: 21536606].
20 Sutton M, Nikolova S, Boaden R, Lester H, McDonald R, Roland M. Reduced mortality with hospital pay for performance in England. New England Journal of Medicine. Nov. 8. 2012;367(19):1821-1828. [pmid: 23134382].
21 Van Herck P, De Smedt D, Annemans L, Remmen R, Rosenthal MB, Sermeus W. Systematic review: Effects, design choices, and context of pay-for-performance in health care. BMC health services research. 2010;10:247-247. [pmid: 20731816].
22 Werner RM, Bradlow ET. Relationship between Medicare's hospital compare performance measures and mortality rates. JAMA. Dec. 13. 2006;296(22):2694-2702. [pmid: 17164455].
23 Werner RM, Kolstad JT, Stuart EA, Polsky D. The effect of pay-for-performance in hospitals: Lessons for quality improvement. Health Affairs. Apr. 2011;30(4):690-698. [pmid: 21471490].