# INCLUSION AND EXCLUSION CRITERIA

1. Language: Is the full text of the article in English?; Yes...........…..............................................................……............…......Proceed to #2; No .............................................................……….....…………….…. Code X1. STOP; 2. Population: Is the population human participants?; Yes ……….………………………………………………………..…. Proceed to #3; No ………..…. Code X2. Add code B if retaining for background/discussion. STOP; 3. Financial Incentives Intervention: Does the article include information relevant to financial incentive programs?; Yes …………………………………………………….………………. Proceed to #4; No …………… Code X3. Add code B if retaining for background/discussion. STOP; 4. Financial Incentives Setting: Does the article assess pay for performance programs or accountable care organizations in a healthcare setting? Other settings such as businesses or education are excluded. Note: Common incentive programs are the Quality and Outcomes Framework (QOF) and the Hospital Quality Incentive Demonstration (HQID), Advancing Quality (AQ), Clalit P4P, Clinical Practice Improvement Payment (CPIP), Ergebnis Orientierte Vergutung (EOV), Maccabi P4P, National Health Insurance P4P, Performance Management Program (PMP), Physician Integrated Network (PIN), Practice Incentive Program (PIP), Primary Care P4P, Primary Care Renewal Models (PCRM), Program of Quality Improvement (PQI), the Premier Demonstration, the Physycian Group Practice Demonstration, the Integrated Healthcare Association P4P program, the Blue Cross Hawaii P4P program, the Massachusetts multi-plan P4P program, and the Blue Cross Blue Shield of Massachusetts AQC. Common ACOs are the CMS ACO demonstration, the Medicare Pioneer ACO, and the Pioneer ACO.; Yes ………………..................................……………............…............Proceed to #5; No …………… Code X4. Add code B if retaining for background/discussion. STOP; 5. Financial Incentives Population: Does the article assess direct financial incentives or pay for performance programs targeting healthcare providers at the individual, managerial, group, institutional, or system level? Financial incentives targeting patient populations are excluded.; Yes ………………..................................……………............…............Proceed to #6; No ……………….......Code X5.. Add code B if retaining for background/discussion. STOP; 6. Financial Incentives Population: Does the article assess direct financial incentives or pay for performance programs targeting healthcare providers at system level (e.g., capitation, managed care, bundled payments)?; Yes………………..............Code X6. Add code B if retaining for background/discussion. STOP; No……….............................................................................................Proceed to #7; 7. Study Design: Is the study design a randomized controlled trial?; Yes………………..................................……………............…............Code T. STOP; No……………..................................……………................…........... Proceed to #8; 8. Study Design: Is the study design a review (systematic, literature, meta-analysis)?; Yes………………..................................……………............…............Code R. STOP; No..……………..................................……………................…............Proceed to #9; 9. Study Design: Is the study design observational?; Yes………………..................................……………............…............Code O. STOP; No..……………..................................……………................…............Proceed to #10; 10. Study Design: Is the study design a case study, case series, or case report?; Yes………………..................................……………............…............ Code C. STOP; No………………..................................……………................…............Proceed to #11; 11. Study Design: Is the study design qualitative?; Yes………………..................................……………............…............ Code Q. STOP; No..……………..................................……………................…............Proceed to #12; 12. Study Design: Is the article a commentary, letter to the editor or editorial?; Yes………………..................................……………............…............ Code E. STOP; No………………..................................……………................…............Proceed to #13; 13. Study Design: All other study designs, or if the study design is unclear……. Code U. STOP
Key Question 1:; d What are the effects of financial incentive programs on patient outcomes and process of care?; e Are there certain intervention characteristics (ie, size of incentive, target of incentive) that are associated with beneficial effects of these programs?; f For which populations of patients are financial incentive programs most effective?; Key Question 2: Which implementation factors modify the effectiveness of financial incentives? Key Question 3:; e What are the positive unintended consequences related to financial incentives?; f What are the negative unintended consequences related to financial incentives?; g What is the effect of financial incentives on inequality/health disparities?; h What are the intervention and implementation factors that contribute to or mitigate the positive and negative unintended consequences of financial incentive programs?