# SEARCH STRATEGIES

PubMed Searched April 3, 2014

Search String | Notes
(“Reimbursement, Incentive”[Mesh]) OR “Physician Incentive Plans”[Mesh] | Mesh Terms for a specific search of indexed articles
(((publisher[sb]) OR inprocess[sb]) OR pubmednotmedline[sb]) OR oldmedline[sb] AND ((((((((((((((((((((((((((((“pay for performance”[Title/Abstract]) OR p4p[Title/Abstract]) OR pfp[Title/Abstract]) OR “pay for value”[Title/Abstract]) OR “payment for quality”[Title/Abstract]) OR “performance-based payment”[Title/Abstract]) OR “performance-based reimbursement”[Title/Abstract]) OR “performance-based contracting”[Title/Abstract]) OR “performance-based pay”[Title/Abstract]) OR “output-based payment”[Title/Abstract]) OR “incentive reimbursement”[Title/Abstract]) OR “incentive program”[Title/Abstract]) OR “quality based purchasing”[Title/Abstract]) OR “quality incentive”[Title/Abstract]) OR “quality incentives”[Title/Abstract]) OR “quality payment”[Title/Abstract]) OR “quality payments”[Title/Abstract]) OR “quality-based payment”[Title/Abstract])) OR ((“financial incentive”[Title/Abstract]) AND effectiveness[Title/Abstract])) OR ((“financial incentives”[Title/Abstract]) AND effectiveness[Title/Abstract])) OR ((“monetary incentive”[Title/Abstract]) AND effectiveness[Title/Abstract])) OR ((“monetary incentives”[Title/Abstract]) AND effectiveness[Title/Abstract])) OR ((bonus[Title/Abstract]) AND “quality”[Title/Abstract])) OR ((“reward”[Title/Abstract]) AND “quality”[Title/Abstract])) OR ((“quality based”[Title/Abstract]) AND payments[Title/Abstract]) | Keyword terms for a sensitive search of non-indexed articles
Keyword search and MeSH search combined with OR
Limited to publication date after 07/07/2011 | Date of Eij. Search

Pay-For-Performance Literature Review

Search String | Notes
PubMed Searched from December 2012 to current Searched on April 30, 2014
(((((“pay for performance”[Title/Abstract]) OR P4P[Title/Abstract]) OR “pay for value”[Title/Abstract]) OR “financial incentive”[Title/Abstract])) OR ((((bonus OR reward[Title/Abstract])) AND (payment OR reimburse* OR incentive*[Title/Abstract])) AND (quality OR value[Title/Abstract])) | [exact copy of Rand Search] Saved as “P4P Rand Gap Search 1”
((((((((((((Beckman, Howard[Author]) OR Curtin, Kathleen[Author]) OR Casalino, Larry[Author]) OR Dudley, Adams[Author]) OR Doran, Tim[Author]) OR Jha, Ashish[Author]) OR Petersen, Laura[Author]) OR Roland, Martin[Author]) OR Rosenthal, Meredith[Author]) OR Ryan, Andrew[Author]) OR Schneider, Eric[Author]) OR Werner, Rachel[Author]) OR Damberg, Cheryl[Author] | [author search copy of Rand] Saved as “P4P Rand Gap Search 2 authors” After deduplication with search 1, 204 unique results
Searches in Additional Databases are from June 2007 to current Searched on April 30, 2014
CINAHL (EBSCO)
Exact copy of above search strategy (no subject heading used, so no translation needed) | N=1559 After deduplication with PubMed Searches 1319 unique results
PsycInfo(Ovid)
Exact copy of above search strategy (no subject heading used, so no translation needed) | N=1183 After deduplication with PubMed and Cinahl searches 1177 unique results
| The Pay for Performance Literature Review by Rand also searched EconLit and ABInform we do not have access to either of these databases.

Accountable Care Organization Literature Review

Search String | Notes
Pubmed Searched from November 2012 to current Searched on April 30^th^ 2014
((((((quality[Title/Abstract]) OR quality improvement) OR quality indicators, health care) OR “quality of care”) OR “quality of healthcare”)) AND (((accountable care organization*) OR ACO) OR ACOS) | [exact copy of Rand search] N=129 Saved as “ACO Rand Gap Search”
Medline (OVID) [Ovid MEDLINE® without Revisions 1996-April Week 3 2014 ; Ovid MEDLINE ® and Ovid OLDMEDLINE ® 1946 to April Week 3 2014 ; Ovid MEDLINE ® In-Process & Other Non-Indexed Citations April 29,2014] Searched April 30, 2014 and limited to 2012 to current
(share$ adj3 savings).mp. | [exact copy of Rand search] N=53 After deduplication with search above 37 unique results
((accountable adj2 care adj2 organization$).mp OR (ACO OR ACOS).mp. NOT (gene OR genetics$).mp.) AND (Algorithms$.mp OR algorithms/) | N=20 after deduplication with above searches 1 (one) unique citation

Search of WorldCat limited to November 2012 to current searched on April 30, 2014

Search String | Notes
‘((kw: accountable and kw: care and kw: organization* OR kw: aco OR kw: acos)) OR ((kw: shared and kw:saving*)) and 9kw: health* OR kw: medical OR kw: patient* OR kw: physician* OR kw: doctor* OR kw: hospital* OR kw: nurs*)’ | [exact copy of rand search]