# PICOTS TABLE

| KQ1. Effectiveness of pay for performance on patient outcomes and processes of care.; a. What are the effects of pay for performance programs on patient outcomes and process of care?; b. Are there certain intervention characteristics (ie, size of incentive, target of incentive) that are associated with beneficial effects of these programs?; c. For which populations of patients are financial incentive programs most effective? | KQ2. Implementation factors. Which implementation factors modify the effectiveness of pay for performance? | KQ3. Unintended consequences and harms.; a. What are the positive unintended consequences related to pay for performance?; b. What are the negative unintended consequences related to pay for performance?; c. What is the effect of pay for performance on inequality/health disparities?; d. What are the intervention and implementation factors that contribute to or mitigate the positive and negative unintended consequences of financial incentive programs?
Target population | Healthcare providers at the individual, managerial (eg, VISN directors), group, and institutional levels. General patient populations that are part of existing performance measures.
Intervention | Financial incentives/pay-for performance programs
Comparator | Other financial incentive models; non-financial incentives; usual care Examples of factors to examine or compare:; - individual vs provider groups vs institutions; - patient outcomes vs processes of care; - structure of the incentive (eg, relationally determined or can everyone receive award?); - size of the incentive; - target patient population (chronic illness vs disease specific); - how the payment is made (bonus vs salary); - duration of the incentive; - positive vs negative incentives; - other implementation factors
Outcomes | A. Performance measures in patients; - quality-of-life measures; - mortality and morbidity; - health care utilization (eg, admissions, ER visits); - intermediate physiological markers such as blood pressure, HbA1c, and cholesterol; - health promotion outcomes such as smoking cessation, alcohol/substance abuse, and weight loss; B. Processes of care; - Access to care; - Preventive screening; - Referral; - Health behavior education | | Unintended consequences and associated cognitive processes such as motivation (extrinsic vs intrinsic motivation), gaming, risk selection, spillover effects. In addition, unintended consequences may relate to the exacerbation of health disparities in low-income and ethnic minority populations.
Timing | ?
Setting | VHA or other large managed care institutions, other healthcare systems in the US, and healthcare systems in countries with health systems similar to the VHA.
Study designs | Studies with concurrent controls. | | All study designs will be considered