# TECHNICAL EXPERT PANEL

- Edward A. Chow, MD (retired)
  Medical Director, Chinese Community Health Plan
  Executive Director, Chinese Community Health Care Association
  San Francisco Health Commission
- Cheryl Damberg, PhD, MPH
  Senior Principal Researcher, Professor
  Pardee RAND Graduate School
- Laura Damschroder, MS, MPH
  Research Scientist, Ann Arbor VA Center for Clinical Management Research
  Co-implementation Research Coordinator, Diabetes QUERI
  Ann Arbor VA HSR&D Center of Excellence
- Laura Dimmler, MPA, PhD
  Director, School of Healthcare Administration and Leadership
  Associate Professor, Pacific University
- John McConnell, PhD
  Director, Center for Health Systems Effectiveness & Associate Professor, Department of Emergency Medicine, Department of Public Health & Preventative Medicine, and Division of Management, OHSU
- Richard Stenson, MHA, MBA (retired)
  President & CEO, Tuality HealthCare and Tuality Health Alliance
- Kevin Volpp, MD, PhD
  Director, Center for Health Incentives and Behavioral Economics, Leonard Davis Institute
  Director, Penn CMU Roybal P30 Center in Behavioral Economics and Health