# RESULTS

## LITERATURE FLOW

We reviewed 468 titles and abstracts from the electronic search and identified 436 additional references through manual searching of reference lists, input from technical advisors and reviewing conference proceedings of ophthamalogic societies for recent unpublished or ongoing studies.

After applying inclusion/exclusion criteria at the abstract level, seventy full-text articles were reviewed, as shown in Figure 2. Of the full-text articles, we rejected fifty-four that did not meet our inclusion criteria.

Figure 2 Femtosecond laser assisted cataract surgery – literature flow diagram

## KEY QUESTION 1 What is the evidence that FLACS is associated with better patient outcomes than conventional cataract surgery?

### Summary of findings

We identified nine studies addressing the comparative effectiveness of FLACS versus conventional surgery, including three small to medium-sized randomized controlled trials. Six of these studies (and all three of the randomized controlled trials) were conducted at Semmelweis University, Budapest, Hungary, all surgeries having been performed by the same surgeon, using the Alcon LenSx laser. Two studies were conducted in an ophthalmology group practice, at Launceton Eye Hospital, Tasmania, Australia, using the OptiMedica Catalys laser. Sample sizes in these studies ranged from 25 to 400 patients, with follow-up periods extending from two weeks to one year.

The most commonly reported relevant outcomes in these comparative studies were: post-operative corrected distance visual acuity (CDVA); and, effective phacoemulsification time (EPT). We conducted a meta-analysis of CDVA and EPT, but heterogeneity precluded calculation of a reliable summary effect estimate. The results of individual studies are presented in Figures 3 and 4. Overall, there was low evidence of comparative benefit of FLACS from three randomized controlled trials and six observational studies. There were no significant differences noted between groups for CDVA outcomes. EPT outcomes were mixed, with results either comparable between FSL and conventional cataract surgery groups or favoring FSL groups. No studies addressed quality of life measures. Methodological concerns were noted regarding the generalizability of studies conducted from limited sites and potential sample selection bias from enrollment into FSL and conventional surgery groups.

Figure 3 Corrected distance visual acuity (CDVA) in studies comparing femtosecond laser with conventional cataract surgery

Figure 4 Effective phacoemulsification time (EPT) in studies comparing femtosecond laser with conventional cataract surgery

### Detailed findings

Table 1 shows the detailed characteristics and findings of the included comparative studies.

Table 1 Characteristics and findings of studies of femtosecond laser assisted cataract surgery

Author, Year; Study Setting | Study objectives | Study Design; Number of Patients; Length of Follow-up; Laser Used | Mean age; % male; cataract density (LOC III score) | KQ 1: Benefits | KQ 2: Adverse events | KQ 3: Surgeon experience
Conrad- Hengerer, 2012^21^ University of Bochum, Germany | Laser grid-size efficacy/safety study | Prospective cohort study of two FLACS techniques— no conventional surgery comparator (single surgeon) N=160 patients 4 weeks OptiMedica Catalys | Tx group 1 (350 grid): 71±12; 32%; 3.7±08 Tx group 2 (500 grid): 72±11; 60%; 3.5±08 | EPT: Tx group 1=.03±.05 seconds Tx group 2=.21±.26 seconds p-value=NR | Intraoperative: -Free-floating anterior capsule noted in all eyes -12 2^nd^ docking attempts Post operative: None noted | NA
Schultz, 2013^22^ University of Bochum, Germany | Record IOP at various time-points during FLACS | Case series (2 surgeons) N=100 patients 1 hour OptiMedica Catalys | 70±12; 51%; NR | NA | Intraoperative: 27.6±5.5mmHg increase in mean IOP | NA
Mihaltz, 2011^17^ Semmelweis University Budapest, Hungary | Compare FSL and conventional capsulotomies | Prospective cohort study of FLACS and conventional surgery (single surgeon) N=91 patients 6 months Alcon LenSx | Tx group: 75.0; 21%; NR C group: 70.7; 18%; NR | CDVA: Tx group=.97±.08 C group= .97±.06 p>.05 | NR | NA
Nagy, 2012^20^ Semmelweis University Budapest, Hungary | Compare FSL and conventional OCT macular thickness changes | Prospective cohort study of FLACS and conventional surgery (single surgeon) N=25 patients 8 weeks Alcon LenSx | Tx group: 55.17±17.25; 58.3%; NR C group: 62.00±14.27; 38.5%; NR | CDVA: Tx group= 1.0±0.0 C group= .95±.08 p-value=NR EPT: Differences between Tx and C were NS | None noted | NA
Nagy, 2011^26^ Semmelweis University Budapest, Hungary | Compare FSL and conventional capsulotomies and IOL decentration | Randomized trial of FLACS and conventional surgery (single surgeon) N=111 patients 1 week Alcon LenSx | Tx group: 65±13; 27.8%; NR C group: 68±15; 29.8%; NR | NA | NR | NA
Kranitz, 2012^15^ Semmelweis University Budapest, Hungary | Compare FSL and conventional IOL decentration and tilt | Randomized trial of FLACS and conventional surgery (single surgeon) N=45 patients 1 year Alcon LenSx | Tx group: 63.55±13.65; 25%; NR C group: 68.24±10.77; 8%; NR | CDVA: Tx group=0.97±.06 C group= 0.92±.09 p=.03 | NR | NA
Kranitz, 2011^6^ Semmelweis University Budapest, Hungary | Compare FSL and conventional capsulotomy sizing and position | Prospective cohort study of FLACS and conventional surgery (single surgeon) N=40 patients 1 year Alcon LenSx | Tx group: 63.78±13.97; 25%; NR C group: 71.60±1.34; 30%; NR | NA | NR | NA
Takacs, 2012^18^ Semmelweis University Budapest, Hungary | Compare FSL and conventional corneal edema | Prospective cohort study of FLACS and conventional surgery (single surgeon) N=76 patients 1 month Alcon LenSx | Tx group: 65.18±12.42; 26.3%; 2.32±.97 C group: 66.93±10.99; 39.5%; Schiempflug nuclear density 2.13±1.22 | EPT: Tx group=0.10±0.12s C group= 0.12±0.13s p>.05 | Postoperative: Central corneal thickness Tx group=545±31 μm C group= 557±42 μm p>.05 | NA
Filkorn, 2012^14^ Semmelweis University Budapest, Hungary | Compare FSL and conventional IOL power calculation and refractive outcome | Randomized trial of FLACS and conventional surgery (single surgeon) N=134 patients 12 weeks Alcon LenSx | Tx group: 65.18±12.6; NR; NR C group: 64.37±12.37; NR; NR | CDVA: Tx group=0.93±0.87 C group= 0.95±0.91 p>.05 | NR | NA
Ecsedy, 2011^19^ Semmelweis University Budapest, Hungary | Compare FSL and conventional macular thickness | Prospective cohort of FLACS and conventional surgery (single surgeon) N=40 patients 1 month Alcon LenSx | Tx group: 64 (median); 40%; NR C group: 66 (median); 25%; NR | CDVA (median): Tx group=0.83±0.65 C group= 0.95±0.87 EPT (median, IQR): Tx group=0.08s (0.03-0.12) C group= 0.08s (0.03-0.15) p=0.94 | NA | NA
Abell, 2012^4^ Launceton Eye Hospital, Tasmania, Australia | Compare FSL and conventional phacoemulsification safety and effectiveness | Parallel cohort study of FLACS and conventional surgery (5 surgeons) N=400 patients 2-3 weeks OptiMedica Catalys | Tx group: 73.3±9.9; 48%; 2.81±.82 (Pentacam Nuclear Staging) C group: 71.8±10.8; 42%; 2.71±0.72 (Pentacam Nuclear Staging) | EPT: Tx group=4.3 sec C group= 14.3 sec p<0.0001 | Intraoperative: Reported for the Tx group, Imperfect capsulotomy= 0.5% Focal adhesions= 2% Reduction of pupil size= 3% Capsular rupture= 0.5% Aborted (claustrophobia), n=1 Aborted (unsafe postioning), n=1 Aborted (patient movement), n=2 Reported for C group: No adverse events noted | EPT: 1^st^ 100 cases=3.52+-4.18 secs 2^nd^ 100 cases=4.75+-5.22 secs; P=0.0674
Abell, 2013^16^ Tasmanian Eye Institute, Launceton, Tasmania, Australia | Compare FSL and conventional phacoemulsification, visual outcomes and endothelial loss | Case control study of FLACS and conventional surgery (single surgeon) N=150 patients 3 weeks OptiMedica Catalys | Tx group: 72.8±10.5; 46%;2.59±0.71 (Pentacam Nuclear Staging) C group: 71.8±10.8; 45.1%; 2.52±0.72 (Pentacam Nuclear Staging) p>0.05 | CDVA: Tx group=0.67 C group= 0.67 p>0.05 EPT: Tx group=2.33±2.28s C group=14.24±10.90 s p<0.0001 | Postoperative: Endothelial loss Tx group= -143.8±208.3 C group= -224±188.95 p=0.022 | NA
Kerr, 2013^25^ Tasmanian Eye Institute, Launceton, Tasmania, Australia | Analyze the course of IOP during FSL cataract surgery | Prospective non-comparative cohort study N=25 patients immediate postop OptiMedica Catalys | 72.5±7.7; 40%; NR | NA | Intraoperative: Mean baseline IOP=17.5±2.4mmHg Vacuum On IOP=28.9±3.2mmHg FSL application=36.0±4.4 mmHg p<0.001 (1-way ANOVA compared to baseline) | NA
Bali, 2012^23^; Roberts, 2013^24^ Vision Eye Institute, Chatswood, Australia | Describe intraoperative complications and evaluate learning curve with FLS cataract surgery | Prospective non-comparative cohort study (7 surgeons) N=1500 patients (N=200 initial, N=1300 subsequent) 3 months Alcon LenSx | Initial Tx group: 69±9.8; NR; NR Subseqent Tx group: 70.1±10.6; NR; NR | NA | Intraoperative*: -mean docking attempts=1.5 -suction breaks=5 eyes -small anterior capsule tags=10.5% -posterior capsular rupture=3.5% (*These findings pertain to the initial study of N=200 patients) | Complications with increasing surgeon experience (docking attempts; anterior capsular tears; post capsular tears; IOL dislocation)*: 1^st^ 200 cases= 1.5; 4%; 3.5%; 2% 2^nd^ 1300 cases= 1.05; 0.31%; 0.31%; 0% p<0.001 for all comparisons (*These findings pertain to the initial and subsequent study of N=1500 patients)

Abbreviations: C = Conventional cataract surgery group; Tx = femtosecond laser cataract surgery treatment group; N = number of subjects; LOC III score = lens opacities classification system III grading score; EPT = effective phacoemulsification time; IOP = intraocular pressure; CDVA=corrected distance visual acuity; UDVA=uncorrected distance visual acuity; BDVA=best distance visual acuity; NOS = not otherwise specified; NR = not reported; NA = not applicable; NS = not statistically significant; FU = follow-up; FSL=femtosecond laser; FLACS=femtosecond laser-assisted cataract surgery.

A randomized trial (N=134) with 77 patients in the FSL group and 57 patients in the conventional cataract surgery group utilized the Alcon LenSx laser.14 Baseline age between groups was similar, with cataract density not reported. Reported post-operative CDVA at twelve weeks was 0.93±0.87 in the FSL group and 0.95±0.91 in the conventional group (p>0.05). Another randomized trial (N=45) compared a FSL group (n=25) versus a conventional group (n=20) using the Alcon LenSx laser.15 At one year, post-operative CDVA was measured as .97±.06 for the FSL group versus .92±.09 for the conventional group (p=.03).

One study (n=400) enrolled consecutive patients electing for FSL (n=200). Patients who did not elect FSL underwent conventional phacoemulsification cataract surgery (n=200) and were considered the control group.4 Five surgeons participated in this study, for which the OptiMedica Catalys laser was used in the FSL arm. Both groups were statistically similar at baseline in age and cataract density. EPT was reported as significantly decreased in the FSL group (4.3 vs 14.3 seconds; p<0.001).

Another study by the same author (N=201) was a case-control design, with a single surgeon using the OptiMedica Catalys laser in the FSL cases (n=150), compared to conventional cataract surgery controls (n=51).16 Baseline demographics and cataract density were similar statistically between groups. CDVA outcomes at three weeks post-operatively measured 0.67 in both groups (p>0.05). EPT was significantly decreased in the FSL group (2.33±2.28 vs 14.24±10.90 seconds; p<0.0001).

Another study (N=91) compared FSL groups (n=48) with conventional surgery groups (n=43), using the Alcon LenSx laser.17 Baseline age and gender distribution was similar between groups but cataract density was not reported. At six months, post-operative CDVA was reported as as .97±.08 in the FSL group and .97±.06 in the conventional group (p>.05).

One study (N=76) enrolled equal groups (n=38) of FSL and conventional surgery patients, using the AlconLenSx laser.18 Demographic characteristics and cataract density at baseline were reported as being similar between the groups. The study excluded patients with denser cataracts, low cooperation and FSL procedure contraindications such as corneal scarring. EPT was reported as 0.10±0.12 for the FSL group and 0.12±0.13 seconds for the conventional group (p>0.05).

Another study (N=40) enrolled patients into FSL (n=20) and conventional groups (n=20) using the Alcon LenSx laser.19 Outcomes reported which compared FSL and conventional surgery groups were EPT (0.08 for FSL vs 0.08 for conventional; p=0.94) and one month post-operative CDVA (0.83±.0.65 for FSL vs 0.95±0.87 for conventional; p-value not reported).

A final study (N=25) enrolled patients in FSL (n=12) and conventional surgery (n=13) groups with similar baseline demographic characteristics, with cataract density not reported.20 EPT was reported as not statistically different between groups. Eight week post-operative CDVA was measured as 1.0±0.0 for the FSL group and .95±.08 for the conventional group (p-value not reported).

#### Meta-analyses of CDVA and EPT

Figures 3 and 4 present plots of meta-analyses conducted on CDVA and EPT outcomes. Relatively few studies reported these outcomes in a consistent and combinable manner. We identified four studies for the meta-analysis of CDVA16,17,19,20 and four studies for the meta-analysis of EPT.4,16,18,19 Given the moderate to substantial heterogeneity among studies (for CDVA I-squared=63.9%, p = 0.040; for EPT I-squared=94.1%, p = 0.000), a summary estimate of the effect is unreliable. Instead, we present the forest plots as visual aids to illustrate individual study results.

The scales for CDVA used across studies were consistent when converted to decimal units, therefore we used mean difference to combine study results. We found moderate heterogeneity among studies. Consequently, we conducted a sensitivity analysis by excluding a presumed outlying study.19 We found that this exclusion did not alleviate concerns with heterogeneity, nor did it change the substantive findings of the meta-analytic results. As a result, we included all four studies in the meta-analyses, represented in Figure 3 which illustrates no significant difference in CDVA for patients undergoing FSL or conventional procedures.

For EPT, we used the ratio of the mean to reduce the variation among studies and estimated the relative difference in EPT. Despite these efforts, there was still significant heterogeneity among studies. We would have included one additional study in the meta-analysis,20 but this study did not report a point estimate for EPT and could not be included. Figure 4 shows what appears to be a reduction of mean EPT in the FLACS group, compared to the conventional group. However, since the 95% confidence interval includes one, this difference is not significant.

## KEY QUESTION 2A What are the adverse effects that have been reported for FLACS?

### Summary of findings

Seven studies were identified addressing adverse effects unique to FLACS. Sample sizes in these studies ranged from 25 to 1300 patients, with follow-up periods extending from immediately following the procedure to three months post-operative.

We grouped the adverse event outcomes in these studies by either: 1) those occurring as a result of difficulties with the laser-patient interface; or, 2) the change in intraocular pressure (IOP) measured during the FLACS procedure. Five studies reported difficulties related to the laser interface with the ocular surface (including the orbital structures). Two studies measured intraocular pressure (IOP) fluctuation during FLACS procedures. A small proportion of patients experienced suction breaks, second docking attempts and aborted procedure adverse events. FSL application is also associated with an increase in IOP. Overall, we found moderate to low strength of evidence for adverse events with methodological concerns from enrollment criteria used for FSL surgery groups.

### Detailed findings

#### Laser interface events

One study compared EPT in two groups of patients (n=80 per group) undergoing FLACS with two different laser grid-sizes.21 In both groups, using the OptiMedica Catalys FSL, a total of twelve patients required a second docking attempt. No other intra-operative or subsequent adverse events were noted in either group after four weeks of follow-up.

A case series study (N=100) of IOP measurements during FLACS noted no patients had suction loss during FSL (Catalys) treatment.22 No adverse events were reported at the one hour post-operative timepoint.

A comparative safety and effectiveness study of 400 patients (n=200 per group), reported four patients in the FSL (Catalys) group, for whom the laser procedure was aborted.4 One patient was claustrophobic, one with kyphosis made postioning unsafe and two patients had excessive movement during the procedure.

A case series of the initial 200 patients undergoing FLACS (Alcon LenSx) in a single group practice reported intraoperative complications of this cohort.23 Mean docking attempts were reported as 1.5 per eye. Five eyes had suction breaks during the FSL procedure, with no adverse events noted with the manual completion of the surgeries. A continuation study of this same group's experience, using the same FSL platform, reported intraoperative complications of FLACS for a subsequent series of 1300 patients.24 No additional adverse effects unique to FLACS were noted, though data related to surgical experience was reported (see findings for Key Question 3).

#### Intraocular pressure events

The interface of any of the FSL platforms with the optical surface causes an increase in intraocular pressure (IOP).8 This occurs due to applanation and/or suction applied during FSL docking and laser application. This laser-patient interface must be stable throughout the phases of imaging, capsulotomy, corneal incisions and photodisruptive pre-fragmentation of the cataract. The various FSL platforms use different docking mechanisms, which can affect the degree to which the IOP increases during the FLACS procedure.1 Both of the IOP studies included in this review utilized the OptiMedica Catalys FSL.

One case series (N=100) recorded IOP at two time-points—during and one hour following the FLACS procedure.22 Mean IOP increased to 27.6 ±5.5 mmHg in this cohort. Patients were queried post-operatively and none reported experiencing amaurosis (blindness), during FLACS.

An additional case series study to analyze IOP during FLACS (N=25), reported measurements at baseline and at various time-points.25 Mean baseline IOP (17.4±2.4 mmHg), increased to 36.0±4.4 mmHg during FSL application. This represented a mean increase from baseline of 18.5±4.7 mmHg.

## KEY QUESTION 2B What is the risk of adverse effects from FLACS compared to the risk associated with conventional cataract surgery?

### Summary of findings

Nine studies addressed the adverse effects of FLACS compared to conventional cataract surgery. Sample sizes in these studies ranged from 25 to 400 patients, with follow-up periods extending from one week to one year.

We grouped the adverse event outcomes of these studies by the ocular structures which were affected. Five of these studies reported, variously: capsulotomy configuration, position and the resultant effects on IOL decentration and refractive outcomes. Two of these studies reported post-operative corneal edema by measuring either corneal thickness or corneal endothelial cell loss. An additional two studies compared post-operative macular thickness and morphology, as measured by optical coherence tomography (OCT). The FSL and control groups were similar for post-operative corneal thickness and macular edema measurements, with corneal endothelial cell loss decreased in the FSL group in one study. Overall, we found moderate to low strength of evidence for comparative adverse events with methodological concerns from enrollment criteria used for the FSL and conventional surgery groups.

### Detailed findings

#### Capsulotomy sequelae

Five comparative studies of capsulotomy characteristics reported multiple aberrometry and geometric measurement outcomes.6,14,15,17,26 However, none of the prioritized adverse events were reported in any of these studies (see Appendix C).

#### Corneal morphology and function

One study (n=76) compared central corneal thickness by pachymetry measurement at one month post-operatively in equal numbers of patients. At enrollment, patients with dense cataracts were excluded from participation in the study.18 These authors reported no statistical difference between corneal thickness between FSL vs. conventional groups (545±31μm vs. 557±42 μm; p>.05) Another study reported decreased corneal endothelial cell loss in the FSL group (n=150) vs. the control group (n=51) at three weeks post-operatively (-143.8±208.3 vs -224±188.95; p=0.02).16

#### Macular morphology

Two studies compared macular thickness between FSL and conventional surgery groups via OCT measurements. One of these studies (n=25) noted no statistically significant differences in macular thickness between groups in all but one retinal layer post-operatively at eight weeks.20 Here, the outer nuclear layer was thicker in the control group (96.5±10.46μm vs 87.54±10.31μm; p=.04). Another study (n=40) measured macular thickness post-operatively at one month, reporting no significant differences between groups in macular total volume, foveal or outer macular ring thickness.19

## KEY QUESTION 3 What is the evidence that the experience of the surgeon is associated with adverse effects of FLACS?

### Summary of findings

Three studies reported outcomes relevant to the experience of the surgeon in performing the FLACS procedure. Sample sizes in these studies ranged from 200 to 1300 patients, with follow-up periods extending from two weeks to three months. Overall, one of the studies found no significant differences between outcomes for initial and subsequent groups of patients undergoing FLACS, while on the other hand two studies from the same team of researchers found significantly fewer complications associated with greater experience with FLACS.

There were methodological concerns from enrollment criteria used for the FSL and conventional surgery groups.

### Detailed findings

One study compared the safety and effectiveness of FSL to conventional surgery in 200 consecutive patients who elected FSL or conventional surgery procedures.4 Further sub-analysis of the FSL group into initial (n=100) and subsequent (n=100) patients reported outcomes for EPT and docking attempts. No statistically significant differences were noted between initial and subsequent groups for either of these FSL parameters (mean EPT: 3.52±4.18 for FSL vs. 4.75±5.22 for conventional group; p=0.0674; mean docking attempts: 1.49±0.64 for FSL vs. 1.36±0.79 for conventional group; p=0.2025).

Another study compared intraoperative complications in four groups of consecutive patients undergoing FLACS (n=50 in each group) who were followed for three months.23 The number of mean docking attempts was greater in the initial 100 patients than in the subsequent 100 patients (1.85 for FSL vs 1.2 for conventional group; p<0.05). The seven surgeons participating in this study were all from a single group practice. Three of these surgeons had prior “extensive” experience with the FSL in LASIK surgery. The study noted these “refractive surgeons” had statistically fewer complications than did the “non-refractive surgeons” in their first 100 cases. No significant difference in complications between these surgeon groups was noted after these initial 100 cases.

An extension of the above study23 reported complication rates in a subsequent consecutive patient group (n=1300) treated with FLACS by the same surgical group practice, compared to the initial group of 200 patients.24 Patients were followed for three months. Complications were significantly decreased in the subsequent group for docking attempts (1.5 for FSL vs 1.05 for conventional group), anterior capsular tears (4% for FSL vs 0.31% for conventional group), posterior capsular tears (3.5% for FSL vs 0.31% for conventional group) and posterior lens dislocation (2% for FSL vs 0% for conventional group). The reported p-values for all comparisons were p<0.001.

## ONGOING STUDIES

We reviewed recent conference proceedings from ophthalmologic societies for topic relevance. We coded conference abstracts that potentially address one or more of our key questions and describe the study characteristics in Table 2.

Table 2 Characteristics of upcoming studies presented at recent conference proceedings or registered on ClinicalTrials.gov

Author, Year | Abstract Title | Conference, Location, Year | Population; Study Design; Setting | Study Objectives
Chee (ongoing study, registered in 2012)27 | Prospective Evaluation of Circularity and Diameter of Femtosecond Laser Versus Manual Anterior Capsulotomy in Singapore National Eye Centre (1118) | ClinicalTrials.gov Online only | N≈22 Prospective, randomized study Singapore National Eye Centre, Singapore | Evaluate the circularity of the anterior capsulotomy performed by FLACS versus conventional cataract surgery.
Chee, 2013^28^ | Early Visual Outcomes of First 100 Cases of Femtosecond Laser–Assisted Cataract Surgery in Ophthalmic Institution in Singapore | ASCRS Paper. San Francisco, CA. 2013 | N=100 eyes Prospective cohort study Singapore | Examine safety and visual outcomes of FLACS versus control cases.
Culbertson, 2012^29^ | Anterior Capsule Healing Patterns Following Femtosecond Laser–Assisted Cataract Surgery | ASCRS Paper,San Francisco, CA. 2013 | N=24 patients Prospective randomized study NR | To evaluate size and shape of femtosecond laser anterior capsulotomy during 4 week healing.
Doane, 2011^30^ | Effect on Refractive Predictability of Manual Versus Femtosecond Laser Capsulotomy in Cataract Surgery With Multifocal IOL Implantation | ASCRS Paper. San Francisco, CA. 2013 | N=50 patients NR NR | To compare refractive predictability of multifocal IOL performance with manual versus laser refractive capsulotomy.
Gayton, 2013^31^ | Clinical Experience With Femtosecond Laser–Assisted Cataract Surgery | ASCRS Paper. San Francisco, CA. 2013 | N=5 patients NR NR | Femtosecond laser technology use in cataract surgery has several differences that can cause complications: 1) the anterior capsule is open prior to opening the eye therefore an anterior chamber collapse can result in anterior capsule tears, 2) large gas bubbles posterior to the lens can contribute to capsular block syndrome, 3) an incomplete capsulorrhexis can result in radial extension and 4) laser energy in the nucleus can be directed too anterior, too peripheral and too posterior. Adjustments to the surgical technique can help manage these complications appropriately.
Innovative Medical32 | Clear Corneal Incisions and Arcuate Incisions Utilizing FemtoSecond Laser Technology for Cataract Surgery | ClinicalTrials.gov Online only | N=29 patients Non-Randomized trial Loden Vision Centers, Tennessee, USA | The purpose of this study is to prove the efficacy and safety of the Femtosecond laser to create a clear corneal incision during cataract surgery.
Knorz, 2011^33^ | Comparison of Conventional and Femtosecond Laser-Assisted Phacoemulsification Cataract Surgery on the Macula | ASCRS Paper. San Francisco, CA. 2013 | N=20 patients (N=20 eyes) NR NR | To compare the effect of conventional and femtolaser assisted (LensX) phacoemulsification cataract surgery on the macula, using optical coherence tomography (OCT).
Kurtz, 2009^34^ | A Prospective Single Center Clinical Study for Capsulotomy Using the LenSx 550 Laser | ClinicalTrials.gov Online only | N=60 Prospective Single Center Trial Semmelweis University, Hungary | The objective of this study is to evaluate the ability of the LenSx 550 laser to successfully perform anterior capsulotomy during cataract surgery.
Loden, 2011^35^ | Laser Cataract Surgery With the Femtosecond Laser Technology | ClinicalTrials.gov Online only | N=10 Non-Randomized trial Loden Vision Centers, Tennessee, USA | The purpose of this study is to prove the efficacy and safety of the Femtosecond laser to create a clear corneal incision during cataract surgery.
Mann, 2013^36^ | Reduction of Cumulative Disbursement of Energy With Femtosecond Laser Cataract | ASCRS Paper. San Francisco, CA. 2013 | N=151 eyes NR NR | Pretreatment with the Catalys femtosecond laser for cataract surgery allows for a greater than fifty percent reduction in ultrasound power during cataract extraction with the Infiniti phacoemulsification system with Ozil. This reduction in power may lead to quiter eyes with less edema and inflammation and a quicker visual recovery in the early postoperative period for femtosecond pretreatment group compared to a phacoemulsification group.
Nagy, 2011^37^ | Comparison of Femtosecond Laser and Manual Capsulotomy on Postoperative Quality of Vision | ASCRS Poster. 2011 | N=99 eyes NR NR | To compare postoperative quality of vision outcomes from capsulotomies created using a femto-second laser with those using manual continuous curvilinear capsulorrhexis (CCC).
Naranjo, 2011^38^ | Laser Treatment of the Crystalline Lens | ClinicalTrials.gov Online only | N=75 A Prospective Single-Center Trial Mexico | The objective of this study is to evaluate the feasibility of the LensAR laser system to surgically intervene within the crystalline lens. The primary goal of this initial study is to establish safety parameters as compared with conventional phacoemulsification procedures and to evaluate the ability to provide an accurate and consistent anterior capsular opening (capsulotomy).
Ophthalmic Consultants of Long Island, 2012^39^ | Corneal Sensation and Incidence of Dry Eye Post Refractive Cataract Extraction With FemtoSecond Laser | ClinicalTrials.gov Online only | N=40 Prospective cohort study Ophthalmic Consultants of Long Island – Rockville Centre. USA | The study objective is to assess changes in corneal sensation and dry eye signs and symptoms following cataract extraction/femtosecond arcuate relaxing incisions. Our clinical hypothesis is to determine if a combination of cataract surgery and femtosecond arcuate relaxing incisions lead to a reduction in corneal sensation and the onset or worsening of dry eye signs and symptoms.
Prickett, 2013^40^ | Initial Resident Experience Performing Cataract Surgery with and without Femtosecond Laser (Conference proceeding) | ARVO Poster Session, 2013 | N=44 eyes Observational study University of Illinois, USA | To document and compare the resident experience performing cataract surgery with femtosecond laser with standard cataract surgery performed without femtosecond laser.
Sándor, 2013^41^ | Comparison of early corneal peripherial endothelial cell loss following femtosecond laser – assisted cataract surgery and conventional phacoemulsification (Conference proceeding) | ARVO Poster Session, 2013 | N=15 patients (N=15 eyes) Observational study Semmelweis University, Hungary | To compare early corneal peripherial endothelial cell loss after femtosecond laser – assisted cataract surgery and conventional phacoemulsification, using non-contact specular microscopy.
Seibel, 2012^42^ | Femtosecond Laser Pretreatment to Facilitate Cataract Surgery in Brunescent Cataracts | ASCRS Poster. 2012 | Eye n=68 NR NR | To evaluate ease of removal of laser-fragmented cataracts.
Shah, 2013^43^ | Assessment of Ease of Adoption of Femtosecond Cataract Surgery | ASCRS Poster San Francisco,CA 2013 | NR NR NR | Examine the ease of use, compatibility of the system and quality of outcomes with femtosecond laser-assisted cataract surgery.
Vote, 2013^44^ | Postoperative Corneal Oedema and Endothelial Cell Loss After Femtosecond Laser Pretreatment Compared With Conventional Cataract Surgery | ASCRS Paper. San Francisco, CA. 2013 | Patient n=140 Prospective case-control study NR | Femtosecond laser pretreatment followed by phacoemulsification cataract surgery is associated with a significant reduction in postoperative oedema and endothelial cell loss compared to conventional phacoemulsification.
Weinstock, 2013^45^ | Outcomes of Femtosecond Laser Cataract Surgery With Standardized Surgical Planning | ASCRS Poster San Francisco,CA 2013 | N=180 eyes Prospective, non-randomized, multi-center study NR | The use of standardized surgical planning in femtosecond laser cataract surgery provided uncomplicated surgical planning with reproducible excellent outcomes.

Abbreviations: ASCRS = American Society of Cataract and Refractive Surgery; ASCRS♦ASO= A Symposium and Congress; ARVO= Association for Research in Vision and Ophthalmology; SPIE = the International Society for Optical Engineering; NR= not reported