# REFERENCES

1 Uy HS, Edwards K, Curtis N. Femtosecond phacoemulsification: the business and the medicine. Current Opinion in Ophthalmology. Jan. 2012;23(1):33-39. [pmid: 22081031].
2 Palanker DV, Blumenkranz MS, Andersen D, et al. Femtosecond laser-assisted cataract surgery with integrated optical coherence tomography. Science Translational Medicine. Nov. 17. 2010;2(58):58ra85.
3 He L, Sheehy K, Culbertson W. Femtosecond laser-assisted cataract surgery. Current Opinion in Ophthalmology. Jan. 2011;22(1):43-52. [pmid: 21150606].
4 Abell RG, Kerr NM, Vote BJ. Catalys femtosecond laser-assisted cataract surgery compared to conventional cataract surgery. Clin Experiment Ophthalmol. Oct. 19. 2012.
5 Masket S, Sarayba M, Ignacio T, Fram N. Femtosecond laser-assisted cataract incisions: architectural stability and reproducibility. Journal of Cataract & Refractive Surgery. Jun. 2010;36(6):1048-1049. [pmid: 20494782].
6 Kranitz K, Takacs A, Mihaltz K, Kovacs I, Knorz MC, Nagy ZZ. Femtosecond laser capsulotomy and manual continuous curvilinear capsulorrhexis parameters and their effects on intraocular lens centration. Journal of Refractive Surgery. Aug. 2011;27(8):558-563. [pmid: 21710951].
7 VA Office of Inspector General. Evaluation of Cataract Surgeries and Outcomes in Veterans Health Administration Facilities. Report No. 11-02487-158. Department ofVeterans Affairs. Washington, DC 20420. 2013.
8 Moshirfar M, Churgin DS, Hsu M. Femtosecond laser-assisted cataract surgery: a current review. Middle East Afr J Ophthalmol. Oct. 2011;18(4):285-291. [pmid: 22224016].
9 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa Hospital Research Institute. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. May 8, 2012.
10 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Methods Guide for Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Rockville, MD. 2010.
11 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. Apr. 2011;64(4):383-394. [pmid: 21195583].
12 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. Jama. Apr. 19. 2000;283(15):2008-2012. [pmid: 10789670].
13 Higgins JPT, Altman DG, editors. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008. Version 5.0.1. The Cochrane Collaboration. 2008. Accessed at www.cochrane-handbook.org on 25 Nov 2013.2008.
14 Filkorn T, Kovacs I, Takacs A, Horvath E, Knorz MC, Nagy ZZ. Comparison of IOL power calculation and refractive outcome after laser refractive cataract surgery with a femtosecond laser versus conventional phacoemulsification. Journal of Refractive Surgery. Aug. 2012;28(8):540-544. [pmid: 22785062].
15 Kranitz K, Mihaltz K, Sandor GL, Takacs A, Knorz MC, Nagy ZZ. Intraocular lens tilt and decentration measured by Scheimpflug camera following manual or femtosecond laser-created continuous circular capsulotomy. J Refract Surg. Apr. 2012;28(4):259-263. [pmid: 22496437].
16 Abell RG, Kerr NM, Vote BJ. Toward Zero Effective Phacoemulsification Time Using Femtosecond Laser Pretreatment. Ophthalmology. May. 2013;120(5):942-948. [pmid: 23465860].
17 Mihaltz K, Knorz MC, Alio JL, et al. Internal aberrations and optical quality after femtosecond laser anterior capsulotomy in cataract surgery. Journal of Refractive Surgery. Oct. 2011;27(10):711-716. [pmid: 21986002].
18 Takacs AI, Kovacs I, Mihaltz K, Filkorn T, Knorz MC, Nagy ZZ. Central corneal volume and endothelial cell count following femtosecond laser-assisted refractive cataract surgery compared to conventional phacoemulsification. Journal of Refractive Surgery. Jun. 2012;28(6):387-391. [pmid: 22589291].
19 Ecsedy M, Mihaltz K, Kovacs I, Takacs A, Filkorn T, Nagy ZZ. Effect of femtosecond laser cataract surgery on the macula. Journal of Refractive Surgery. Oct. 2011;27(10):717-722. [pmid: 21877677].
20 Nagy ZZ, Ecsedy M, Kovacs I, et al. Macular morphology assessed by optical coherence tomography image segmentation after femtosecond laser-assisted and standard cataract surgery. Journal of Cataract & Refractive Surgery. Jun. 2012;38(6):941-946. [pmid: 22624892].
21 Conrad-Hengerer I, Hengerer FH, Schultz T, Dick HB. Effect of femtosecond laser fragmentation of the nucleus with different softening grid sizes on effective phaco time in cataract surgery. Journal of Cataract & Refractive Surgery. Nov. 2012;38(11):1888-1894. [pmid: 22980639].
22 Schultz T, Conrad-Hengerer I, Hengerer FH, Dick HB. Intraocular pressure variation during femtosecond laser-assisted cataract surgery using a fluid-filled interface. Journal of Cataract & Refractive Surgery. Jan. 2013;39(1):22-27. [pmid: 23245360].
23 Bali SJ, Hodge C, Lawless M, Roberts TV, Sutton G. Early experience with the femtosecond laser for cataract surgery. Ophthalmology. May. 2012;119(5):891-899. [pmid: 22361311].
24 Roberts TV, Lawless M, Bali SJ, Hodge C, Sutton G. Surgical outcomes and safety of femtosecond laser cataract surgery: a prospective study of 1500 consecutive cases. Ophthalmology. Feb. 2013;120(2):227-233. [pmid: 23218822].
25 Kerr NM, Abell RG, Vote BJ, Toh T. Intraocular pressure during femtosecond laser pretreatment of cataract. J Cataract Refract Surg. Mar. 2013;39(3):339-342. [pmid: 23312148].
26 Nagy ZZ, Kranitz K, Takacs AI, Mihaltz K, Kovacs I, Knorz MC. Comparison of intraocular lens decentration parameters after femtosecond and manual capsulotomies. Journal of Refractive Surgery. Aug. 2011;27(8):564-569. [pmid: 21688765].
27 Chee SP. Prospective Evaluation of Circularity and Diameter of Femtosecond Laser Versus Manual Anterior Capsulotomy in Singapore National Eye Centre (1118)Ongoing study; registered in 2012. http://clinicaltrials.gov/show/NCT01693211.
28 Chee S, Ti S. Early Visual Outcomes of First 100 Cases of Femtosecond Laser–Assisted Cataract Surgery in Ophthalmic Institution in Singapore. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
29 Culbertson W. Anterior Capsule Healing Patterns Following Femtosecond Laser–Assisted Cataract Surgery. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
30 Doane JF. Effect on Refractive Predictability of Manual Versus Femtosecond Laser Capsulotomy in Cataract Surgery With Multifocal IOL Implantation. Paper presented at: American Society of Cataract and Refractive Surgery. 2011. San Francisco, CA.
31 Gayton JL. Clinical Experience With Femtosecond Laser–Assisted Cataract Surgery. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
32 Innovative Medical. Clear Corneal Incisions and Arcuate Incisions Utilizing FemtoSecond Laser Technology for Cataract SurgeryStudy completed in 2012, no results posted. http://clinicaltrials.gov/show/NCT01383057.
33 Knorz MC. Comparison of Conventional and Femtosecond Laser-Assisted Phacoemulsification Cataract Surgery on the Macula. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
34 Kurtz RM, Sarayba M. A Prospective Single Center Clinical Study for Capsulotomy Using the LenSx 550 LaserStudy completed, no results posted; registered 2009. http://clinicaltrials.gov/show/NCT00959322.
35 Loden J. Laser Cataract Surgery With the Femtosecond Laser TechnologyCompleted study, no results posted; registered 2011. http://clinicaltrials.gov/show/NCT01382823.
36 Mann PM. Reduction of Cumulative Disbursement of Energy With Femtosecond Laser Cataract. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
37 Nagy Z. Comparison of Femtosecond Laser and Manual Capsulotomy on Postoperative Quality of Vision. Paper presented at: American Society for Cataract and Refractive Surgery. 2011.
38 Naranjo R, Villar J. Laser Treatment of the Crystalline LensOngoing study; registered 2009. http://clinicaltrials.gov/show/NCT01001117.
39 Ophthalmic Consultants of Long Island. Corneal Sensation and Incidence of Dry Eye Post Refractive Cataract Extraction With FemtoSecond LaserOngoing study; registered 2011. http://clinicaltrials.gov/show/NCT01441895.
40 Prickett AL, Cortina MS, Hou JH, De la Cruz J. Initial Resident Experience Performing Cataract Surgery with and without Femtosecond Laser. Conference proceedings of the Association for Research in Vision and Ophthalmology (ARVO). 2013. Poster Session A0184.
41 Sándor GL, Takács ÁI, Kranitz K, Juhasz E, Kovacs I, Nagy Z. Comparison of early corneal peripherial endothelial cell loss following femtosecond laser – assisted cataract surgery and conventional phacoemulsification. Conference proceedings of the Association for Research in Vision and Ophthalmology (ARVO). 2013. Poster Session D0284.
42 Seibel B. Femtosecond Laser Pretreatment to Facilitate Cataract Surgery in Brunescent Cataracts. Paper presented at: American Society for Cataract and Refractive Surgery. 2012.
43 Shah S. Assessment of Ease of Adoption of Femtosecond Cataract Surgery. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
44 Vote BJ, Kerr NM, Abell RG. Postoperative Corneal Oedema and Endothelial Cell Loss After Femtosecond Laser Pretreatment Compared With Conventional Cataract Surgery. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
45 Weinstock RJ, Cionni RJ, Thompson VM. Outcomes of Femtosecond Laser Cataract Surgery With Standardized Surgical Planning. Paper presented at: American Society of Cataract and Refractive Surgery. 2013. San Francisco, CA.
46 Reddy KP, Kandulla J, Auffarth GU. Effectiveness and safety of femtosecond laser-assisted lens fragmentation and anterior capsulotomy versus the manual technique in cataract surgery. J Cataract Refract Surg. Sep. 2013;39(9):1297-1306. [pmid: 23988242].
47 Abell RG, Allen PL, Vote BJ. Anterior chamber flare after femtosecond laser-assisted cataract surgery. J Cataract Refract Surg. Sep. 2013;39(9):1321-1326. [pmid: 23850229].
48 Conrad-Hengerer I, Al Juburi M, Schultz T, Hengerer FH, Dick HB. Corneal endothelial cell loss and corneal thickness in conventional compared with femtosecond laser-assisted cataract surgery: Three-month follow-up. J Cataract Refract Surg. Sep. 2013;39(9):1307-1313. [pmid: 23871112].
49 Stein JD. Serious adverse events after cataract surgery. Current Opinion in Ophthalmology. May. 2012;23(3):219-225. [pmid: 22450221].
50 Alio JL. Cataract surgery with femtosecond lasers. Saudi J Ophthalmol. Jul. 2011;25(3):219-223. [pmid: 23960928].
51 Riau AK, Angunawela RI, Chaurasia SS, Tan DT, Mehta JS. Effect of different femtosecond laser-firing patterns on collagen disruption during refractive lenticule extraction. Journal of cataract and refractive surgery. 2012;38(8):1467-1475. [pmid: 22814054].