# METHODS

## TOPIC DEVELOPMENT

The following key questions guiding this systematic review were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators and consultation with content experts and key stakeholders.

### Key Question 1 What is the evidence that FLACS is associated with better patient outcomes than conventional cataract surgery?

- Population: Adults undergoing cataract surgery.
  Considerations: femtosecond laser surgery is relatively contraindicated in patients with: advanced glaucoma, high anxiety, tremors, dementia, facial or ocular anatomy that precludes adequate LASER docking (i.e. small palpebral fissures, prominent brows, irregular corneal surfaces) and previous refractive surgery or corneal opacities.
- Intervention: Femtosecond laser technology is used in cataract surgery to assist or replace aspects of conventional cataract surgery, including corneal incisions, capsulotomy and lens fragmentation. Lasers at or near the point of commercial release include: Alcon LenSx (Alcon Laboratories, Fort Worth, TX, USA); OptiMedica Catalys (OptiMedica Corp, Santa Clara, CA, USA); LensAR (LensAR Inc, Winter Park, FL, USA); VICTUS (Bausch + Lomb, Aliso Viejo, CA, USA; and Technolas Perfect Vision GmbH, Munich, Germany); IntraLase FS; and iFS Laser Systems (Abbott Medical Optics, Abbott Park, IL, USA).
  Only a subset of these lasers is currently FDA approved for cataract surgery.8 Still, this review is inclusive of studies concerning any femtosecond laser used for cataract surgery applications regardless of FDA status.
- Comparators: Conventional cataract surgery, defined as small-incision, phacoemulsification with posterior-chamber intraocular lenses (IOL) implantation.
- Outcomes: Short-term patient outcomes: visual acuity—post -operative day 1. Long-term patient outcomes: visual acuity—after post-operative day 1 (e.g., one week, one month, ninety days); quality of life measures.
- Study design: Controlled studies including randomized controlled trials and non-randomized controlled clinical trials, as well as observational studies comparing FLACS to conventional cataract surgery.
  Excluded study designs: Case reports, case series and studies that do not report primary data such as editorials and non-systematic reviews.
- Timing: Our operational definition to be used for timing of patient outcomes is as follows:
  - Short-term—patient outcomes on post-operative day 1
  - Long term—patient outcomes > after post-operative day 1 (no upper limit).
  Considerations: Standards for reporting timing of post-operative outcomes often have variable time-horizons. For example, potential harms such as CME or IOL decentration, may be reported from as early as post-operative day one or after months to years in some studies.
- Setting: Any.

### Key Question 2a What are the adverse effects that have been reported for FLACS?

### Key Question 2b What is the risk of adverse effects from FLACS compared to the risk associated with conventional cataract surgery?

- Population: Adults undergoing cataract surgery.
- Intervention: Femtosecond laser technology is used to assist or replace steps in conventional cataract surgery, including corneal incisions, capsulotomy and lens fragmentation.
- Comparators: Conventional cataract surgery.
- Outcomes: Surgical complications (intra-operative and post-operative).
  Intra-operative: | 1. capsular blockage syndrome; 2. dislocated nucleus; 3. capsular tear; 4. docking failure
  Post-operative: | 1. infection; 2. retinal swelling/cystoid macular edema (CME); 3. corneal edema; 4. intraocular (IOL) decentration
- Study design: Controlled studies and observational study designs (cohort and case-control studies), case reports and case series.
- Timing: Short-term—intraoperative, post-operative day 1. Long term—patient outcomes > after post-operative day 1 (no upper limit).
- Setting: Any.

### Key Question 3 What is the evidence that the experience of the surgeon is associated with adverse effects of FLACS?

- Population: Adults undergoing cataract surgery.
- Intervention: Femtosecond laser technology is used in cataract surgery to assist or replace aspects of conventional cataract surgery, including corneal incisions, capsulotomy and lens fragmentation.
- Comparators: Conventional cataract surgery.
- Study designs: Controlled studies and observational study designs including economic evaluation studies (cohort and case-control studies).
  Excluded study designs: Case reports, case series and studies that do not report primary data such as editorials and non-systematic reviews.
- Outcomes: Surgical complications (intra-operative and post-operative).
  Intra-operative: | 1. capsular blockage syndrome; 2. dislocated nucleus; 3. capsular tear; 4. docking failure
  Post-operative: | 1. infection; 2. retinal swelling/cystoid macular edema (CME); 3. corneal edema; 4. intraocular (IOL) decentration
- Timing: Short-term—patient outcomes on post-operative day 1. Long term—patient outcomes > after post-operative day 1 (no upper limit).
- Setting: Any.

Appendix C presents these eligibility criteria for considered studies in a PICOTS (Population, Intervention, Comparators, Outcomes, Timing and Setting) table. Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic Framework

## SEARCH STRATEGY

Search strategies were developed in consultation with a research librarian from database inception to May 2013. We conducted a primary review of the literature by systematically searching, reviewing and analyzing the scientific evidence as it pertained to the research questions. To identify relevant articles, we began by searching MEDLINE^®^, the Cochrane library, ClinicalTrials.gov, premarket notification 510(k) summaries from the FDA and conference proceedings of societies for ophthalmology and refractive surgery. Searches were conducted from April 2013 to July 2013, with no limit on year of publication.

We searched ClinicalTrials.gov to identify in-progress or unpublished studies. We searched conference proceedings of ophthalmologic societies and topic specific journals, including the following: The American Society of Cataract and Refractive Surgery; Journal of Cataract & Refractive Surgery; American Academy of Ophthalmology; Ophthalmology; International Society of Refractive Surgery; American Academy of Ophthalmic Executives; The Foundation of the American Academy of Ophthalmology; The Royal College of Ophthalmologists; COS Conference Papers Index; and Proceedings First (OCLC). Appendix A provides the search strategy in detail. We obtained additional articles from reference lists of pertinent studies, reviews, editorials and by consulting experts. All citations were imported into an electronic database (EndNote X1).

## STUDY SELECTION

Two reviewers assessed abstracts of citations identified from literature searches for relevance. Full-text articles of relevant abstracts were retrieved for further review. Each article retrieved was independently reviewed by two reviewers using eligibility criteria (Appendix B). Included studies were published in the English language and involved adults undergoing cataract surgery using femtosecond laser technologies.

Using pre-specified inclusion/exclusion criteria, titles and abstracts were reviewed for potential relevance to the key questions. At the full-text screening stage, two independent reviewers assessed each study. Disagreements were discussed to come to a final decision on inclusion/ exclusion. If the two independent reviewers could not come to an agreement, a third reviewer assessed the study in question. For all excluded studies, full-text reviewers also came to unanimous agreement on the reason for exclusion. Articles meeting eligibility criteria were included for data abstraction.

## DATA ABSTRACTION

Data from published reports were abstracted into a customized database by one investigator and reviewed for accuracy by a second investigator. From each study, we abstracted the following: study design, objectives, setting (country, institution information), population characteristics (including sex, age, medical comorbidities), subject eligibility and exclusion criteria, number of subjects, duration of follow-up, the study and comparator interventions, health outcomes, adverse events and number and experience of the surgeons.

## STUDY QUALITY

We adapted the Newcastle Ottowa tool9 to assess the quality of observational studies. For randomized studies, we used the Cochrane Collaboration tool for assessing the risk of bias. Two reviewers independently assessed the quality of each study and disagreements were resolved through discussion. We added additional criteria as necessary to account for methodological issues specific to this subject area, such as financial conflicts of interest and the number of studies produced by a small number of authors and coauthors (i.e., same team replication). We did not report an overall summary assessment for observational studies because there are no validated criteria for doing so.10

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group.11 We present the summary of evidence in Table 3. The GRADE method considers the consistency, coherence and applicability of a body of evidence, as well as the internal validity of individual studies, to classify the grade of evidence across outcomes as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## DATA SYNTHESIS

We summarized the primary literature by abstracting relevant data, developing data tables and qualitatively synthesizing the literature for each key question. We determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis) to estimate summary effects depending on the volume of relevant literature, conceptual homogeneity of the studies and completeness of results reporting. We conducted meta-analyses of commonly reported outcomes, following the MOOSE guidelines for conducting meta-analyses of observational studies.12 All analyses were conducted using StataIC 11 (StataCorp, College Station, Texas). We assessed the presence of statistical heterogeneity among the studies by using standard chi-square tests and the magnitude of heterogeneity by using the I^2^ statistic.13 We explored models using both mean and ratio of means based on a random effects model. However, because of concerns of heterogeneity among studies we do not report the combined estimates and instead present forest plots as a visual aid to illustrate individual study results.