# DISCUSSION

We conducted a systematic review of the current FLACS literature, comparing the benefits of FLACS to conventional cataract surgery, the adverse events associated with FLACS and the influence of increasing surgical experience on these adverse events. We found moderate evidence of comparable CDVA outcomes between FLACS and conventional cataract surgery groups. We noted limited evidence for a reduction of EPT in the FSL compared to the conventional cataract surgery group. Furthermore, meta-analyses found no statistically significant differences between FSL and conventional groups in either CDVA or EPT. No studies reported findings related to quality of life outcomes or cost effectiveness of FLACS relative to conventional cataract surgery.

Several studies reporting adverse effects unique to FLACS noted docking failures to be common. These failures were successfully managed by a subsequent docking attempt. Rarely did these failures require aborting the FSL procedure, with successful completion by converting to conventional cataract surgery, resulting in no adverse outcomes. There were moderate adverse findings of orbital or ocular anatomical laser interface difficulties, causing either aborted FSL procedures or exclusion of these patients from the studies. The Catalys FSL platform, using the liquid-filled interface, was utilized in two studies of serial IOP measurements during and after the procedure. Transient elevation of IOP into the mid-20 to mid-30 mm Hg range during the FSL precedure was noted in these studies. No studies were found for IOP measurements using the Alcon LenSx FSL, which utilizes suction to effect docking. This interface mechanism has been noted to cause marked IOP elevations in other corneal refractive surgical applications.3

Most of the included studies reported on the comparative risks of adverse effects between FSL and conventional cataract surgery. Reports of adverse events were similar between FSL and conventional groups, including IOL positioning, corneal thickness, macular edema and residual refractive error. The rate of postoperative corneal endothelial cell was noted to be significantly decreased in the FSL group in only one included medium-sized study (N=201).16

The association between the experience of the surgeon and FLACS adverse effects was limited to three eligible studies, two of which were related. These studies reported mixed results of surgical experience reducing the incidence of FLACS adverse events, with very low strength of evidence.

We conducted an update search on September 18, 2013 and found two observational studies that reported decreased EPT with FSL,46,47 consistent with the trend seen among other studies included in our review. We also identified two recent studies that found decreased initial postoperative inflammation with FSL,47,48 although after three months no differences were observed between FSL and conventional cataract surgery.48

Although there were significant limitations with the body of literature, we found FLACS to be comparable to conventional cataract surgery. We found no evidence that FLACS differs from conventional cataract surgery on measures of safety and effectiveness. The unique risks associated with FLACS are primarily related to laser docking interface difficulties, which may be reduced with increasing surgical experience with the procedure. The comparative adverse event risks of FLACS and conventional surgery were similar. Complications rates in FLACS cohorts were found to be reduced or unchanged by surgical experience in the included studies of this review.

There were methodological concerns for the included studies that represent potential sources of bias that threaten the validity of study findings. Many studies had small sample sizes, with the potential for difficulty in analyzing data for low-risk events,49 and follow-up times and outcomes reported were often variable, making study comparisons problematic. In addition, study methods were often unclear, particularly with regard to the application of inclusion and exclusion criteria for FSL treatment groups and the enrollment of treatment and control cohorts. Often studies excluded patients with denser cataracts, comorbidities and those deemed uncooperative. In addition, many study protocols called for patients self-selecting into FSL or conventional surgery groups. Further, most studies evaluated similarities between treatment and control groups only for gender and age.

All of the FSL platforms require the orbital anatomy to be accessible and the cornea to be suitable for successful laser docking. Two of the eligible studies in this review specifically excluded patients in the FSL group, who had “deep-set eyes”4 or “narrow palpebral fissures”.24 Similarly, an adequate laser/corneal interface requires a pristine corneal surface. Most of the studies excluded patients from the laser treatment groups with corneal pathology such as scarring, previous corneal surgery and high degrees of corneal astigmatism, limiting generalizability of findings to those patients for whom FLACS is appropriate.4,14,16,18,21-25

Similar exclusion criteria issues were noted in studies for dense cataracts18,22 as the FSL is unable to perform photo disruption in tissues that are not optically clear.4,50 The Schiempflug nuclear density grading (LOC III score of increasing density from 1-5) was reported at baseline in a minority of the comparative studies.4,16,18 Here, in the FSL groups, the LOCS III scores ranged from 2.13 to 2.59; only patients with mild to moderate density cataracts were enrolled, specifically excluding patients with dense cataracts.

The FSL procedure is unsuitable for patients who are unable to cooperate, for any reason. Thus, some studies excluded patients from the FSL groups who were “uncooperative”,18 or with hemifacial spasm.24 Transient elevations of IOP limit FLACS suitability for patients with high-risk glaucoma, another exclusion criteria found in many studies. Patients with other medical co-morbidities, such as kyphosis and movement or behavioral disorders, were found to be unacceptable for FLACS procedures. The careful patient selection in studies of FLACS to date may significantly limit the generalizability of findings to VA cataract surgical populations.

Operating room logistics and efficiencies are made more cumbersome by the need for a two-suite surgery staging for each patient.1 Each patient undergoes the FLACS procedure beneath the FLS platform and is moved into a second, sterile location in the operating room for the completion of the surgery. In addition, multiple laser docking attempts can extend the operating room time for each patient. This added complexity and duration of the surgical procedure may adversely impact surgical backlogs.

Device manufacturers are closely associated with most of the study authors and the majority of included studies (all but two) report financial conflicts of interest. Eligible studies were also clustered around a limited number of geographic sites and conducted by the same team of coauthors. All four of the included randomized trials were conducted by the same research group, and every surgery (FSL or conventional) was completed by the same surgeon study co-author. It is also unclear whether or not there was any overlap in the study patient populations of these trials, given they were conducted at the same site and in what seems to be a similar timeframe.

Most of the studies in this review involved highly experienced, high-volume surgeons, supported by similarly experienced surgical teams. These findings may not apply to VA surgeons, especially with regard to ophthalmology residency training programs. The few studies which reported decreasing complication rates with increased surgical experience must be considered when evaluating the suitability of introducing FLACS into a training program environment.

The eligible studies in this review did not include any cost-effectiveness or quality of life data. The non-laser portion of the disposable costs for FLACS and conventional phacoemulsification surgery are comparable, as both involve irrigation, aspiration and phacoemulsification. The additional, incremental cost of FLACS is the $150-300 per patient charge for the sterile, single-use patient interface device.50 The approximate initial cost of the FSL equipment is $500,000. Future studies assessing the cost-effectiveness and incremental changes to quality of life associated with FLACS and conventional cataract surgery will be needed to provide additional information to guide procedure adoption decisions.

## FUTURE STUDIES

Modern, conventional cataract surgery is associated with very low risks of sight-threatening complications.49 In this review, FLACS appears to be comparable to conventional cataract surgery, though the evidence base is limited. Greater numbers of randomized control trials (RCTs) with larger sample cohort sizes are desirable to allow detection of the relative risks of rare events. Assessment blinding is problematic, as FLACS patients are aware of their participation in the FSL treatment arm, as are the assessors due to the unique appearance of the laser versus the manual incisions. Studies that are sufficiently powered and well designed should be insulated from the device manufacturers to eliminate this potential bias. Head to head trials between FSL platforms should assist in informing potential users of their relative risks and benefits. Studies from groups other than those few included in this review should provide a more global perspective of FLACS. The applicability of the FSL technology to the overall cataract population has not been explored by the eligible studies in this review. Further studies regarding the suitability of FSL for patients with the co-morbidities found in the VA population (i.e. dense cataracts, glaucoma, corneal pathology) and studies assessing the costs relative to benefits expected from FLACS and conventional surgery will be key to determining the feasibility of widespread adoption of this procedure.

## CONCLUSIONS

This systematic review found visual outcomes (CDVA) and EPT to be similar in FLACS and conventional surgery, while quality of life and cost-effectiveness outcomes were not reported. The evidence for the relative benefit of FLACS was limited by reliance on small to moderately-sized prospective cohort studies, nearly all of which had stated financial conflicts of interest. Adverse events unique to FLACS involved difficulties in laser docking or patient suitability for the procedure. Many patients were excluded from the FSL treatment groups for orbital, corneal, cataract density, or medical co-morbidities. Comparative adverse events in FLACS and conventional surgery were found to be similar for IOL positioning, corneal thickness, macular edema and residual refractive error. A few studies reported mixed results of the effect of surgical experience on the incidence of FLACS adverse events.

Table 3 Summary of the evidence on the effects of femtosecond laser assisted cataract surgery

Outcome | For each study design: Number of studies (combined sample size) | Findings | Strength of Evidence | Comments
Visual acuity | 2 RCTs (N=189) 4 NRCS (N=306) | No significant differences | Low | No differences in visual acuity outcomes found in either of the randomized trials. Unclear risk of bias for trials, low consistency, coherence and applicability of estimated effects across studies, small to medium sample sizes and conflicts of interest lower the strength of evidence.
Effective phacoemulsification time | 1 RCT (N=76) 4 NRCS (N=615) 1 NCS (N=160) | Mixed findings | Low | Trial found no significant reduction in EPT for FSL group. Two of the large nonrandomized studies (N=550) reported significant reductions in favor of FLACS. Remaining three studies found no significant differences. Unclear risk of bias for trial, low consistency, coherence and applicability of estimated effects across studies and conflicts of interest lower the strength of evidence.
Quality of life | None | None | No evidence | None of the included studies reported on quality of life outcomes.
Intraoperative complications^*^ | 3 NRCS (N=1,900) 3 NCS (N=285) | Higher IOP for FLACS; Few additional complications for FLACS | Moderate to Low | Low incidence of complications with FLACS, though increases in IOP reported across studies. Low applicability of estimated effects lowers the strength of evidence.
Postoperative complications^**^ | 1 RCT (N=76) 1 NRCS (N=150) 1 NCS (N=160) | Mixed findings | Low | Trial found no significant differences and medium-sized cohort study (N=150) found significantly reduced endothelial loss for the FLACS group. Unclear risk of bias for trial, low consistency and coherence of estimated effects across studies, small to medium sample sizes and conflicts of interest lower the strength of evidence.
Costs | None | None | No evidence | None of the included studies reported on costs of FLACS compared to conventional cataract surgery.

Abbreviations: RCT = randomized controlled trial; NRCS = non-randomized comparative studies; NCS = non-comparative studies; FLACS = femtosecond laser assisted cataract surgery; EPT = effective phacoemulsification time; IOP = intraocular pressure.

* Intraoperative complications include: capsular blockage, capsular tear, dislocated nucleus, docking failure

** Postoperative complications include: infection, retinal swelling/cystoid macular edema, intraocular decentration, corneal edema