# ASSESSMENT OF METHODOLOGIC QUALITY IN STUDIES OF FEMTOSECOND LASER ASSISTED CATARACT SURGERY

The Newcastle-Ottowa tool for observational studies

Author, year; study setting | Non-biased selection | High overall loss to follow-up or differential loss to follow-up | Adequate duration of follow-up | Outcomes pre-specified and defined | Ascertainment techniques adequately described | Non-biased and adequate ascertainment methods | Statistical analysis of potential confounders
Conrad-Hengerer, 2012^21^ University of Bochum, Germany | Unclear “A standardized lens-softening pattern… was used in 1 study group and a 500 mm grid size in the other study group after randomization” | No | NA | Yes | Yes | Yes | No “Descriptive statistical analysis was performed using SPSS. The ttest was used to compare the sample means. Boxplots were used for analysis.”
Schultz, 2013^22^ University of Bochum, Germany | No “Patients scheduled for elective femtosecond laser–assisted cataract surgery” | NA. Primary outcome was intraoperative. | NA | Yes | Yes | Yes | Unclear
Mihaltz, 2011^17^ Semmelweis University Budapest, Hungary | Unclear “Femtosecond capsulotomies were performed in 48 eyes of 43 patients … Continuous curvilinear capsulorrhexis by forceps was performed on 51 eyes of 38 patients, which served as a control group” | No | Yes | Yes | Yes | Yes | No “Statistical analysis was performed by comparing two samples at a time using the Student t test for analysis of mean visual and refractive values and intraocular optical quality parameters in both study groups”
Nagy, 2012^20^ Semmelweis University Budapest, Hungary | No “The study group comprised 12 eyes of 12 patients. The control group comprised 13 eyes of 13 patients.” | No | Yes | Yes | Yes | Yes | Yes
Nagy, 2011^26^ Semmelweis University Budapest, Hungary | Yes “Using computer randomization, patients and their right/left eyes were randomly selected for femtosecond and manual surgery.” | No | Yes | Yes | Yes | Yes | Unclear
Kranitz, 2012^15^ Semmelweis University Budapest, Hungary | Yes “Randomization was done using computer-generated tables” | No | Yes | Yes | Yes | Yes | Unclear
Takacs, 2012^18^ Semmelweis University Budapest, Hungary | Yes “Patients were randomly assigned (using computer randomization) to either group by the surgeon” | No | Yes | Yes | Yes | Yes | Unclear
Filkorn, 2012^14^ Semmelweis University Budapest, Hungary | Yes “Patients were randomly assigned to each group using a computer randomization chart.” | No | Yes | Yes | Yes | Yes | Unclear
Kranitz, 2011^6^ Semmelweis University Budapest, Hungary | No ““Femtosecond capsulotomies were carried out in 20 eyes of 20 patients and manual CCC was performed in 20 eyes of 20 patients undergoing cataract sugery with IOL implantation.” | No | Yes | Yes | Yes | Yes | Unclear. GEE models used to correct for correlated measures for patients having both eyes operated.
Ecsedy, 2011^19^ Semmelweis University Budapest, Hungary | No “…femtosecond laser-assisted phacoemulsification with the LenSx laser system was carried out in 20 eyes from 20 patients with cataract. Traditional phacoemulsification was performed on 20 eyes from 20 additional patients with cataract.” | No | Yes | Yes | Yes | Yes | Unclear
Abell, 2012^4^ Launceton Eye Hospital, Tasmania, Australia | No “Patients who underwent conventional cataract surgery (i.e. did not have femtosecond laser) were classified as the control group” | No | Yes | Yes | Yes | Yes | Unclear
Abell, 2013^16^ Tasmanian Eye Institute, Launceton, Tasmania, Australia | No “Cases (n=150) included patients who elected to undergo femtosecond laser pretreatment “ | No | Yes | Yes | Yes | Yes | Unclear
Kerr, 2013^25^ Tasmanian Eye Institute, Launceton, Tasmania, Australia | No “Consecutive patients having femtosecond laser pretreatment to cataract extraction were recruited” | No | Yes | Yes | Yes | Yes | Unclear
Bali, 2012^23^ Vision Eye Institute, Chatswood, Australia | No “…study included the initial 200 consecutive femtosecond laser cataract surgeries, refractive lens exchange surgeries, or both performed at the Vision Eye Institute “ | No | Yes | Yes | Yes | Yes | No
Roberts, 2013^24^ Vision Eye Institute, Chatswood, Australia | No “…prospective, multicenter, nonrandomized, postmarket evaluation undertaken after local regulatory approval was obtained for clinical use of the LenSx system” | NA. Primary outcome was intraoperative. | NA | Yes | Yes | Yes | Unclear

Abbreviations: NA = not applicable.

The Cochrane Collaboration's tool for assessing risk of bias

Author, year; study setting | Sequence generation | Allocation concealment | Blinding of participants, personnel and outcome assessors | Incomplete outcome data | Selective outcome reporting | Risk of bias^*^
Nagy, 2011^26^ Semmelweis University Budapest, Hungary | Low: “Using computer randomization, patients and their right/left eyes were randomly selected for femtosecond and manual surgery.” | Unclear: No information provided | Unclear: No information provided, but one of the authors completed all surgeries, suggesting a lack of personnel blinding. | Low: Report no attrition and exclusions appear to all be pre-randomization. | Unclear: Reported on key outcomes but unclear if other outcomes were assessed but not reported. | Unclear
Kranitz, 2012^15^ Semmelweis University Budapest, Hungary | Low: “Randomization was done using computer-generated tables” | Unclear: No information provided | Unclear: No information provided, but one of the authors completed all surgeries, suggesting a lack of personnel blinding. | Low: Report no attrition and exclusions appear to all be pre-randomization. | Unclear: Reported on key outcomes but unclear if other outcomes were assessed but not reported. | Unclear
Takacs, 2012^18^ Semmelweis University Budapest, Hungary | Low: “Patients were randomly assigned (using computer randomization) to either group by the surgeon” | Unclear: No information provided | Unclear: No information provided, but one of the authors completed all surgeries, suggesting a lack of personnel blinding | Low: Report no attrition and exclusions appear to all be pre-randomization. | Unclear: Reported on key outcomes but unclear if other outcomes were assessed but not reported. | Unclear
Filkorn, 2012^14^ Semmelweis University Budapest, Hungary | Low: “Patients were randomly assigned to each group using a computer randomization chart” | Unclear: No information provided | Unclear: No information provided, but one of the authors completed all surgeries, suggesting a lack of personnel blinding. | Low: Report no attrition and exclusions appear to all be pre-randomization. | Unclear: Reported on key outcomes but unclear if other outcomes were assessed but not reported. | Unclear

* Risk of bias:

- Low = Plausible bias unlikely to seriously alter the results
- Unclear = Plausible bias that raises some doubt about the results
- High = Plausible bias that seriously weakens confidence in the results.