# ELIGIBILITY CHARACTERISTICS OF STUDIES (PICOTS TABLE)

| KQ1: Benefits What is the evidence that FLACS is associated with better outcomes than conventional cataract surgery? | KQ2: Adverse effects KQ2a: What are the adverse effects that have been reported for FLACS? KQ2b: What is the evidence that FLACS is associated with a lower risk of adverse effects than conventional cataract surgery? | KQ3: Learning curve What is the evidence that the experience of the surgeon is associated with adverse effects of FLACS?
Population | Adults undergoing cataract surgery. Considerations: femtosecond laser surgery is relatively contraindicated in patients with: advanced glaucoma, high anxiety, tremors, dementia, facial or ocular anatomy that precludes adequate LASER docking (i.e. small palpebral fissures, prominent brows) and previous refractive surgery or corneal opacities.
Intervention | Femtosecond laser technology is used in cataract surgery to assist or replace aspects of conventional cataract surgery, including corneal incisions, capsulotomy and lens fragmentation. Lasers at or near the point of commercial release include: Alcon LenSx (Alcon Laboratories, Fort Worth, TX, USA), OptiMedica Catalys (OptiMedica Corp, Santa Clara, CA, USA), LensAR (LensAR Inc, Winter Park, FL, USA), VICTUS (Bausch + Lomb, Aliso Viejo, CA, USA; and Technolas Perfect Vision GmbH, Munich, Germany), IntraLase FS and iFS Laser Systems (Abbott Medical Optics, Abbott Park, IL, USA). This review is inclusive of studies of any femtosecond laser used for cataract surgery applications regardless of FDA status.
Comparator | Conventional cataract surgery, defined as small-incision phacoemulsification with planned posterior-chamber intraocular lenses (IOL).
Included study designs | Controlled studies including randomized controlled trials, non-randomized controlled clinical trials, controlled before/after studies and observational studies | Controlled studies, observational studies, case-control studies, case reports, case series. | Controlled studies; observational study designs including economic evaluation studies).
Excluded study designs | Case reports, case series and studies that do not report primary data such as editorials and non-systematic reviews. | Studies that do not report primary data such as editorials and non-systematic reviews. | Studies that do not report primary data such as editorials and non-systematic reviews.
Outcomes of interest | [underlined: Short-term patient outcomes]; - Visual acuity: post-operative day 1; [underlined: Long-term patient outcomes]; - Visual acuity: after post-operative day 1 (typically recorded post-operative 1 week, 1 month, or 90 days); - Quality of Life (QOL) measures | [underlined: Surgical Complications]; - Intra-operative; - Capsular blockage syndrome; - Dislocated nucleus; - Capsular tear; - Docking failure or loss of docking; - Post-operative; - Infection; - Retinal swelling/Cystoid Macular Edema (CME); - Intraocular (IOL) decentration; - Corneal edema | - Cost; - All other surgical complications listed; - Other adverse effects reported
Timing | Our operational definition to be used for timing of patient outcomes is as follows:; - Short-term—patient outcomes on post-operative day 1; - Long term—patient outcomes > after post-operative day 1 (no upper limit); Considerations: Standards for reporting timing of post-operative outcomes often have variable time-horizons. For example, potential harms such as CME or IOL decentration, may be reported from as early as post-operative day one or after months to years in some studies.
Setting | Any