# INCLUSION/EXCLUSION CRITERIA

Code | Definition | Exclusion criteria/notes | KQ1 – Benefits | KQ2 –Adverse effects | KQ3 – Learning curve
I-1 I-2 I-3 I-SR | Include; addresses KQ1, KQ2, or KQ3 SR = systematic review | | KQ1: What are the benefits of FLACS compared with conventional cataract surgery? | KQ2a: What are the unique risks associated with FLACS? KQ2b: What are the risks of FLACS compared to conventional cataract surgery? | KQ3: What are the intra-operative and post-operative risks of FLACS with regard to the experience f the surgeon?
X1 | Non-English language
X2 | Does not pertain to femtosecond laser technology
X3 | Intervention not in scope | Exclude studies of lasers used for procedures other than cataract surgery | Included interventions: femtosecond lasers used for cataract surgery applications | Same interventions as KQ1 | Same interventions as KQ1
X4 | Study population not in scope | Note: FLACS is contraindicated in the following populations: advanced glaucoma; high anxiety; tremors; dementia; facial or ocular anatomy that precludes docking | Included population: adults undergoing cataract surgery | Same population as KQ1. | Same population as KQ1
X5 | No primary data or study design not in scope, according to each KQ. | Exclude non-systematic or narrative reviews, editorials and opinions. Add code B (e.g. X5-B) to consider using the article in Discussion, or possibly describe the study data as a lower level of evidence. | Include controlled study designs:; - Randomized controlled trials (RCTs); - Non-randomized controlled clinical trials; - Controlled before/after studies | Included study designs for harms:; - Controlled studies; - Quasi-experimental studies; - Cohort studies; - Case-control studies; Excluded study designs:; - Case reports; - Case series | - Same study designs listed for KQ2; - Cost-evaluation studies
X6 | Outcomes that are not in scope | | Short-term patient outcomes:; - Visual acuity: postoperative day 1; Long-term patient outcomes:; - Visual acuity: after postoperative day 1 (typically recorded after 1 week, 1 month, or 90 days); - Quality of life (QOL) measures | Intra-operative complications:; - Capsular blockage syndrome; - Dislocated nucleus; - Capsular tear; Post-operative complications:; - Infection; - Retinal swelling/cystoid edema (CME); - Intraocular (IOL) decentration; - Corneal edema; Other reported harms | - Cost; - All other specified outcomes
X7 | Other reason: specify | Add comments or keywords as needed.
X99 | Full text not accessible
B | Background | Add to any of the above X codes (e.g., X5-B) if the article contains information that may be useful for the introduction, discussion, limitations, future research, or other contextual purposes. Add comments or keywords as needed.