# SEARCH STRATEGY

MEDLINE (PubMed) searched 5/8/2013

Search | Query
#9 | Search (#8) AND #7
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((femtosecond) OR alcon lensx) OR optimedica catalys) OR lensar) OR victus) OR intralase) OR ifs laser systems OR “all-laser Lasik”
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#6) OR #5
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search cataract
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Cataract”51 OR “Cataract Extraction”51

76 unique cites added to EndNote Library

Cochrane Central Register of Controlled Trials and Database of Sytematic Reviews (OVID), searched 5/8/2013

# | Searches
1 | exp Cataract Extraction/ or exp Cataract/ or cataract.mp.
2 | femtosecond.mp.
3 | alcon lensx.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 | optimedica catalys.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5 | lensar.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6 | victus.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 | intralase.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8 | ifs laser systems.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9 | All-laser lasik.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10 | 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11 | 1 and 10

3 unique cites added to EndNote Library

Additional databases, societies and journals, searched 4/17/2013 to 7/9/2013:
1. ASCRS: American Society of Cataract and Refractive Surgery http://www.ascrs.org/ [See also abstracts that were locked out at end of document]
2. Journal of Cataract & Refractive Surgery http://www.jcrsjournal.org/
3. American Academy of Ophthalmology http://www.aao.org/
4. International Society of Refractive Surgery http://www.aao.org/isrs/
5. American Academy of Opthalmic Executives http://www.aao.org/aaoe/
6. The Foundation of the American Academy of Ophthalmology http://www.faao.org/
7. The Royal College of Ophthalmologists http://www.rcophth.ac.uk/
8. The Association for Research in Vision and Ophthalmology http://www.arvo.org/
9. The Journal of Cataract and Refractive Surgery http://www.jcrsjournal.org/
10. Ophthalmology, the official journal of the American Academy of Ophthalmology – http://www.aaojournal.org/
11. COS Conference Papers Index
12. Proceedings First (OCLC)
13. http://clinicaltrials.gov/
14. http://www.fda.gov/