# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE

In this systematic review of FMT for the treatment of CDI, we identified a total of 25 case series and 2 RCTs providing evidence regarding the efficacy of FMT for recurrent, refractory, or an initial episode of CDI, with the bulk of the studies dealing with recurrent CDI. One RCT (n=43) compared FMT to standard therapy and was discontinued early due to a significant difference in recurrence between the FMT group and the 2 control groups, driven in part by lower-than-expected response rates in the control groups. The second RCT (n=20) compared FMT via nasogastric tube to FMT via colonoscopy finding no statistically significant difference between the two approaches. The overall low quality of the available evidence evaluating FMT is one important finding of this report and indicates that additional research is needed. Also important, however, is the large positive effect seen with FMT for CDI, both in the RCTs and in the case series. Overall success (as defined by resolution of symptoms at 3 months or less) was 83% for recurrent disease, and 53% for refractory disease. These rates are substantially higher than the 30% to 70% success rates typically reported with various medical therapies for CDI,6-9 although directly comparing such different studies cannot be done with confidence. Additionally, the optimal medical therapy for patients with multiple recurrences of CDI is unknown, since some small series have reported markedly higher success rates, including up to 88% with the combination of vancomycin followed by rifaximin,11,12 and even 100% with a vancomycin taper.13 However, neither of these regimens has been studied prospectively, and thus the strength of evidence supporting their use remains low. Overall, the available studies regarding FMT for CDI demonstrate a large effect size, but are limited by the availability of only 2 moderate quality RCTs, with only one comparing FMT to antimicrobial therapy.

Primary outcomes among the included trials varied. Among the 21 studies of FMT for recurrent CDI, 9 had a primary outcome of clinical resolution without recurrence, 7 had an outcome of clinical resolution, and 5 did not state a primary outcome. Since nearly all of these studies reported that subjects were on antimicrobials until the time of (or shortly before) the FMT, it is difficult to determine whether the FMT was contributing to resolution of symptoms, avoiding recurrence of CDI, or both. However, in several studies the authors specified that antimicrobials for CDI were administered to ensure that patients were “asymptomatic” at the time of FMT, or had a “reduction of symptoms.” Thus, although stated outcomes included an element of symptom resolution, in most cases FMT appears to be given with the intent to prevent subsequent recurrence, after an initial course of antimicrobial treatment had resolved all or most of the CDI symptoms.

In addition to the reported harms described in Key Question 4, potential harms of FMT include transmission of communicable diseases, procedural complications, immune-modulatory effects, and others. Thus far, the only reported harms clearly attributable to FMT are procedural complications, including minor mucosal tear, microperforation, aspiration, and peritonitis. The other reported potential harms include a flare of previously quiescent ulcerative colitis, potential norovirus acquisition from a healthcare worker, recurrence of bacteremia post-transplant with an organism similar to one seen pre-transplant, and an episode of zoster. The potential link between any of these episodes and the FMT is tenuous, at best. Two recent reports of FMT in immunocompromised patients reported no infectious complications

Acceptability to patients has not been systematically assessed in a patient population with a prior or current episode of CDI, which is presumably the group that would potentially be considering treatment with FMT. A survey of patients with no CDI history reported largely favorable results, but the response rate of less than 50% raises the possibility that respondents might answer differently than non-respondents.

## LIMITATIONS

Our literature search excluded non-English language studies. Hand searching reference lists from recent systematic reviews identified 4 case series, 3 with English language abstracts.66-68 In one series, enrolling patients with CDI (not specified if initial, recurrent, or refractory CDI), resolution of CDI without relapse was reported in 15 of 18 (83%) patients, 17 of whom had FMT via colonoscope.66 Another series included 7 patients with recurrent CDI who received FMT via colonoscopy.67 Initial success was reported for 5 of 7 patients (71%). The other 2 patients achieved a successful outcome after the procedure was repeated with feces from a different donor. The third series reported a success rate of 78% with no deaths or complications.68 The number of patients treated was not reported. The protocol was adopted from studies using an upper GI tract approach. Findings from these small case series are consistent with findings from the English language studies included in our review and we conclude that exclusion of non-English studies did not bias our findings.

Other limitations include the following.

### Publication Bias

Publication bias is a concern for all types of publications, but is likely particularly relevant for case series, including both those reporting the success of FMT, and those reporting regimens such as vancomycin followed by rifaximin and tapering doses of vancomycin. Whereas it has become more accepted for journals to publish RCTs which demonstrate no benefit, or even harms, similar case series are rarely published. The desire to publish a series of successfully treated patients is easily understood, and provides pilot data for future more definitive studies. The desire to publish a series of clinical failures is less easily understood, and the potential benefits to such work are also less tangible.

### Study Quality

With only 2 RCTs included, study quality is a serious limitation of this report. Even well-reported case series have significant quality issues, chief among them being the lack of a direct control group. This necessitates the use of historical controls, which is especially problematic for infectious diseases, since the emergence (and subsequent disappearance) of more virulent or aggressive strains can alter the expected response rate with standard therapy and it is often not known which strain is present, in either clinical or research settings. A direct control group eliminates much of this uncertainty, and prevents both under- and over-estimation of the effect of an intervention.

### Heterogeneity

Given that this review included 25 case series and 2 RCTs, the presence of heterogeneity is not surprising. Additionally, the inclusion of studies from 1958 to 2014 made it likely that disease definitions, treatments, and study designs were different. Follow-up duration, donor selection, and pre-FMT preparations varied considerably; how this affected the study outcomes is unknown.

## APPLICABILITY

Published data on incidence of CDI specific to the VA are more than a decade old.69 At that time, 1% of all patients hospitalized in the VA were diagnosed with CDI.69 According to VA administrative data sources, there were approximately 624,858 hospitalizations in VA facilities in FY 2012, meaning that even a 1% incidence of CDI results in 6,249 cases among inpatients alone. With VA-based studies reporting recurrence rates of 22-30%,70,71 there would be an estimated 1,375 to 1,875 cases of recurrent CDI annually. Actual FY 2012 data regarding CDI diagnoses (available in the inpatient and outpatient treatment files) reveals similar numbers: compared to the estimated 6,249 cases of CDI and 1,375 to 1,875 cases of recurrent CDI among inpatients, 6,046 cases of CDI and 1,517 cases of recurrent CDI were identified using inpatient data sources. When outpatient CDI diagnoses were included, the total number of cases rose from 6,046 to 8,878.

## RESEARCH GAPS/FUTURE RESEARCH

Findings from our evidence report suggest a large beneficial effect of FMT in patients with recurrent or refractory CDI. However, the vast majority of evidence to date comes from case series and the total number of cases with reported outcomes remains relatively low. The 2 reported randomized trials enrolled very few individuals. Confirmation (or refutation) of their findings, assessment of long term harms and determination of broader patient applicability and donor criteria are needed. Furthermore, we are unable to determine if data exist from patients treated with FMT having less favorable results and the potential for substantial positive reporting bias exists. Additionally, conventional methods for rating strength of evidence would classify even well-conducted and reported case series as high risk of bias. Therefore, strength of evidence for the effectiveness of any intervention based on case series (even with large reported effect sizes) would typically be considered insufficient or low at best. Thus the available evidence and the clinical importance of this topic indicate that future research is needed to close knowledge gaps.

Research recommendations to close important gaps include:

1. FMT effectiveness and comparative effectiveness: Additional RCTs comparing FMT to antimicrobial therapy are needed to assess the effectiveness and comparative effectiveness of FMT. Ideally patients and providers should be blinded regarding assigned treatment. Various methods could be used to achieve blinding, especially since FMT is generally administered after a course of antimicrobial therapy, when the patient is typically without CDI symptoms. While full details are beyond the scope of our evidence report such methods could include the use of a placebo enema to be administered after antimicrobial therapy, or even a placebo colonoscopy or nasogastric tube placement. Including 2 FMT arms in such a trial would allow direct comparisons to be made between the different FMT methods chosen, although it would also increase the necessary sample size.
2. Comparison group including more effective pre-FMT treatment: The optimal comparison group for such a study is currently unknown, but based on the low success rate with 2 weeks of vancomycin observed in the recent RCT among individuals with multiple CDI recurrences (with or without the bowel lavage), and the higher success rates reported with other agents or longer courses, any future trials (randomized or not) should carefully consider what agent(s) and duration to use for optimal medical therapy. Further studies of antimicrobial therapy for the treatment of patients with multiple recurrences of CDI would be valuable, both to inform current practice, and to help guide any potential future comparative effectiveness trials.
3. When to offer FMT: If FMT is effective, it is not known whether FMT should be offered after the second, third, fourth, or some other number of recurrences (or possibly even as initial therapy). Thresholds of CDI recurrence that initiate FMT would have a large impact on the number of individuals who are potential candidates for FMT, may alter the balance of benefits to harms, and would have resource implications. In addition to treatment effectiveness, other factors to be considered (and which require more information) include patient preference (including the impact of altering the name of the treatment modality [from fecal microbial transplantation to eg, gastrointestinal recolonization] to enhance patient acceptability), FMT availability, and safety, costs and cost-effectiveness.
4. Donor selection: Information is needed to identify donor selection criteria and screening methods to optimize FMT effectiveness, avoid transmission of harms from FMT donor to recipient, and determine whether patients should be provided with a new donor in the event of having a recurrence after their initial FMT.
5. Fecal material processing and delivery methods: The optimal dose as well as methods to obtain, process and deliver the fecal material are not known. Trials to identify these features would enhance treatment efficacy while minimizing harms.
6. Assessing longer term FMT harms: Little data exist on long-term harms including potential for transmission of diseases from donor to recipient and risk of subsequent CDI.

Research options to evaluate these evidence gaps could include randomized or controlled clinical trials. Additionally, development of a national registry of FMT treated patients and their donors that record standardized assessments of baseline demographics, condition and treatment related characteristics and outcomes could provide valuable additional information. Ongoing trials, evaluating FMT and registered in clinicaltrials.gov for adults or adults and children (Table 12), will provide some important information.

Table 12 Open Trials of FMT for Adults or Adults and Children^a^

Trial Number Design | Title | CDI | Route of FMT
NCT01226992 RCT | Oral Vancomycin Followed by Fecal Transplant Versus Tapering Oral Vancomycin | Recurrent | Enema
NCT01958463 Single Group Assignment | Transplantation of Fecal Microbiota for Clostridium Difficile Infection | Initial, refractory, or recurrent | Colonoscopy
NCT01914731 Single Group Assignment | Fecal Microbiota Transplant for Relapsing Clostridium Difficile Infection in Adults and Children Using a Frozen Encapsulated Inoculum | Refractory, recurrent, or relapsing | Oral capsule
NCT01398969 RCT | Multi-Centre Trial of Fresh vs. Frozen-and-Thawed HBT(Fecal Transplant)for Recurrent CDI | Recurrent | Enema
NCT01905709 Single Group Assignment | Fecal Microbiota Transplantation for C Diff Infection | Recurrent or refractory | Colonoscopy, sigmoidoscopy, or enema
NCT01942447 Non-randomized | Fecal Microbiota Transplantation in Recurrent or Refractory Clostridium Difficile Colitis | Recurrent or refractory | Not specified
NCT01703494 RCT | Fecal Transplant for Relapsing C. Difficile Infection | Relapsing | Colonoscopy

a Source: clinicaltrials.gov; accessed 24 June 2014

## CONCLUSIONS

We found low strength evidence from small RCTs and case series that FMT may have a substantial effect and few short-term adverse events for adults with recurrent CDI. One small moderate quality RCT study found that FMT reduced symptom recurrence compared to standard CDI therapy that included vancomycin and one very small moderate quality RCT found FMT resulted in high symptom resolution rate that did not differ by delivery routes (nasogastric tube vs. colonoscopy). There is insufficient evidence on FMT for patients with refractory CDI and only a single case report for initial treatment of CDI. Evidence is insufficient whether treatment effects vary by FMT donor, preparation or delivery method.