# METHODS

## TOPIC DEVELOPMENT

We developed the key questions and population, intervention, comparator, outcomes, timing, and setting (PICOTS) parameters for the review with input from operational partners and technical expert panel members representing gastroenterology and infectious diseases.

[underlined: Population]: Adults with initial, recurrent, or refractory CDI; we considered initial CDI to be the first occurrence of CDI in a particular subject, recurrent CDI was considered to be an episode of CDI occurring after previous treatment and favorable response for at least one prior episode of CDI, and refractory CDI was considered to be an episode of CDI that was not exhibiting a response to antimicrobial treatment

[underlined: Intervention]: Fecal microbiota transplantation

[underlined: Comparator(s)]: No fecal microbiota transplantation or standard antibiotic therapy; comparative fecal microbiota transplantation methods (eg, duodenum vs. colonoscopy, different donor types)

[underlined: Outcome(s)]: Resolution of symptoms (primary outcome), time to resolution of symptoms, recurrence, mortality, adverse events, readmission, hospitalization, duration of hospitalization

[underlined: Timing]: Short term cure defined as 3 months or less, long term cure defined as greater than 3 months

[underlined: Setting]: Any

## SEARCH STRATEGY

We searched MEDLINE (OVID) for articles published from 1980 through May 2014. Our search was designed to identify studies of any design. We limited the search to studies involving human subjects published in the English language. Search terms included the following Medical Subject Headings (MeSH): Clostridium Infections; Clostridium difficile; Enterocolitis, Pseudomembranous; Feces; and Transplants. The full search strategy is presented in Appendix A. We also searched reference lists of existing systematic reviews and included studies.

## STUDY SELECTION

Abstracts of citations identified from the literature search were assessed for relevance by 2 investigators. We included clinical trials, case series, and case reports of FMT for treatment of recurrent, refractory, or newly diagnosed CDI. We excluded the following:

1. Studies that were not about FMT for CDI or pseudomembranous colitis,
2. Studies that did not report outcomes of interest,
3. Studies that were not case series or were case reports that did not report adverse events, and
4. Studies done in a pediatric/adolescent population.

Full text reports of studies identified as potentially eligible (or indeterminate, eg, title only) were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by 2 investigators. Reasons for excluding a study at full text review were noted.

## DATA ABSTRACTION

Eligible studies were reviewed for outcomes of interest by investigators. Study characteristics (including inclusion/exclusion criteria and intervention characteristics), patient characteristics, donor characteristics, and outcomes data were abstracted onto tables by one investigator and verified by a second. In many cases, it was difficult to ascertain whether our primary outcome, resolution of symptoms, was due to the pre-FMT antimicrobials for CDI, the FMT procedure, or a combination of the two. Similarly, the outcomes of resolution and recurrence were often combined as “resolution of diarrhea without relapse,” or “durable resolution.”

## QUALITY ASSESSMENT

We assessed the quality of RCTs based the following criteria: allocation concealment, blinding, analysis approach, and description of withdrawals – a modification of the Cochrane approach to determining risk of bias.25 We did not assess quality of the case series; the value of assessing quality of case series has not been established.26

## DATA SYNTHESIS

We described and qualitatively compared the patient characteristics, study characteristics, interventions, and findings of included studies. Due to limited reporting we summarized most outcomes narratively. We calculated weighted resolution rates and 95% confidence intervals for the studies of FMT for recurrent CDI stratified by FMT method. We used Comprehensive Meta-analysis Version 2.2 for these calculations.27 There were insufficient studies of refractory CDI or FMT as initial therapy for CDI for numerical synthesis.

## RATING THE BODY OF EVIDENCE

We did not formally rate the overall strength of the body of evidence. Conventional methods for rating strength of evidence, as reported by Owens et al.,28 would classify case series as high risk of bias. Therefore, strength of evidence would typically be considered insufficient or low at best.

## PEER REVIEW

A draft version of this report was reviewed by clinical content experts as well as clinical leadership. Their comments and our responses are presented in Appendix B. The report was modified as needed.