# INTRODUCTION

Since its discovery as the cause of pseudomembranous colitis in 1978,^1,2^ Clostridium difficile (C.difficile) has become an increasingly important pathogen, now rivaling Staphylococcus aureus as a cause of nosocomial infections. Initially, C. difficile infection (CDI) was largely confined to patients with healthcare exposure; however, it is now also affecting those with no or limited contact with the healthcare system.3 In the early 2000s an increase in the incidence and severity of CDI was observed, with a corresponding increase in mortality.4 These increases were attributed to the emergence of an epidemic strain of CDI, associated with resistance to fluoroquinolones and increased toxin production. In part due to the effects of this epidemic strain, the US Centers for Disease Control and Prevention placed C. difficile into its top threat category of “urgent” in its first threat report on antimicrobial resistance,5 a distinction shared only by carbapenem-resistant Enterobacteriaceae and drug-resistant gonorrheae.

Regardless of strain type, a major challenge in treating CDI is the high rate of recurrent disease. Recurrence (defined here as 3 or more unformed stools daily, plus a positive stool test for the presence of C. difficile, after resolution of the initial CDI episode) occurs in 15% to 30% of patients, and among those with a single episode of recurrence, the risk of subsequent episodes increases to 40% to 50%, with the risk of further recurrence increasing after each episode.6,7 Patients in this cycle of multiple treatment/recurrence episodes can experience repeated hospitalizations, clinic visits, deconditioning, malnourishment, and continence issues. These effects are debilitating, and contribute to decreased quality of life and prolonged courses of antimicrobial treatment.7 Antimicrobial treatment for these episodes of recurrent disease yields reported success rates between 30% and 80%, depending on the agent and duration of treatment selected.6-10 Unfortunately, the optimal antimicrobial agent for recurrent CDI, and especially in cases of multiple recurrences, is unknown. The most robust data (ie, randomized trails) for the treatment of recurrent CDI is largely derived from studies including only those with a single recurrence,6 or with a mean of 2.5 prior episodes.8 Other studies of multiple recurrence episodes are of lesser quality, such as a series of 8 patients (with 4 to 8 prior CDI episodes) treated with vancomycin followed by rifaximin.11 This regimen resulted in only a single episode of recurrence (88% success rate); a follow-up publication of 6 further cases from the same group resulted in a 66% success rate.12 Another case series reported 100% success with the use of a prolonged vancomycin taper in 22 subjects with multiple relapses of CDI;13 however, neither of these regimens has been studied prospectively.

Multiple other antimicrobials have been studied as treatments for CDI, including the commonly used metronidazole, and more rarely used agents such as nitazoxanide, bacitracin, and fidaxomicin, a novel agent recently approved by the U.S. Food and Drug Administration (FDA).14 No agent has been shown to be superior to another for initial cure of CDI; however, fidaxomicin use results in a 10% decrease in recurrence compared to oral vancomycin (15% vs. 25%; P=.005).6 Stated as the number-needed-to-treat, treating 10 patients with fidaxomicin will prevent one episode of recurrence. Whether fidaxomicin has a similar favorable effect when used for recurrent CDI is poorly understood.

Central to the pathogenesis of CDI is the alteration of the normal colonic bacteria, also termed the “colonic microbiome.” The initial event that precedes most episodes of CDI is some insult to the colonic microbiome, typically via the administration of systemic antimicrobials, but also occurring after the administration of anti-neoplastic drugs. The normal colonic microbiome provides some degree of protection against pathogenic organisms. The mechanism of this protection is incompletely understood, but has been described as “colonization resistance,” with a healthy microbiome theoretically making it more difficult for pathogens such as C. difficile to colonize the colon.15 Disruption of the microbial diversity of the normal colonic microbiome decreases this level of protection, and if viable C. difficile organisms or spores are ingested, the patient is at high risk of CDI. Unfortunately, most antimicrobial treatments for CDI are not specific to C. difficile, with the result that after successful treatment of a CDI episode, the colonic microbiome remains severely altered, and the patient is at high risk of recurrent CDI—especially since C. difficile spores and organisms are widely dispersed in the environment of patients with CDI, and are difficult to remove or destroy with usual household cleaning.16

Because CDI is characterized by severe alterations in the colonic microbiome, restoring the normal microbiome has been proposed as a method for preventing recurrence. The most widely utilized intervention has been the administration of probiotics, via a variety of delivery methods, including capsules, yogurt, kefir, and other nutritional products. These products provide only a limited number of microorganisms, whereas molecular techniques have demonstrated that the normal colonic microbiome includes thousands of different microorganisms, most of which do not grow on standard culture media, and are poorly characterized.17 Accordingly, fecal microbiota transplantation (FMT) has been increasingly utilized as a treatment for patients with recurrent CDI, utilizing the rationale that to most effectively restore all the organisms that comprise the normal colonic flora, simply import the colonic microbiome of a healthy person. First reported in 1958 (prior to the discovery that C. difficile was the causative agent of pseudomembranous colitis),18 FMT has now been performed in many patients, including more than 500 reported in the medical literature.19 Despite the fact that the majority of cases are from non-controlled case series, the reported success rates of up to 100% have fueled interest in FMT. The recent publication of a randomized controlled trial (RCT) comparing FMT to antimicrobial treatment has further increased interest,20 as has survey data demonstrating both patient and physician acceptance of the procedure.21 Mechanistic studies of stool pre- and post-FMT using genetic sequencing have shown that FMT restores the microbial diversity of the colonic microbiome, possibly restoring the colonization resistance thought to be conferred by this complex mix of microbes.22,23

Several routes of delivery of FMT have been developed, including instillation of donor feces into the upper gastrointestinal (GI) tract via nasogastric or nasojejunal tubes, instillation of feces into the distal colon via retention enema, and instillation of feces into the entire colon via colonoscopy.19 Whether one approach is superior to the others is unknown; similarly, the optimal amount of donor stool, the optimal pre-transplant regimen for the recipient, the necessary donor testing, and the long-term efficacy of FMT are also unknown. Additionally, the regulatory status of FMT is in limbo. In May of 2013 the FDA announced that it considered FMT the administration of a biologic agent to treat disease, thus making it an unapproved drug for which an investigational new drug (IND) application was required. However, in July 2013 the FDA announced that it would exercise “enforcement discretion” regarding the IND requirement for the use of FMT to treat C. difficile infection not responding to standard therapies. The announcement specified that written informed consent should be obtained, and that patients receive counseling regarding both the experimental nature of FMT, and the potential risks.24

The status quo is that FMT appears to be a highly promising, yet unproven, treatment for a disease that is a leading cause of nosocomial infection, and spreading into the community. However, the evidence base supporting FMT is comprised largely of uncontrolled case series, and 2 recent randomized controlled trials. Additionally, the uncertain regulatory climate leaves clinicians facing significant uncertainty. Providers and health systems who currently do not provide FMT may find themselves struggling to balance the desire to provide the best available care versus the concern of adopting an unproven and unlicensed treatment.

## PURPOSE OF REVIEW

The Minneapolis VA Evidence-based Synthesis Program was asked to conduct a systematic review of the evidence regarding the effectiveness of FMT for the treatment of CDI, in part to help guide policy makers within the Veterans Health Administration determine if the evidence supporting FMT was sufficient to implement FMT programs in their facilities. The topic was nominated by Jason Dominitz, MD, MHS on behalf of the VA Gastroenterology Field Advisory Committee. We address the following key questions:

KQ1 What is the effectiveness of fecal microbiota transplantation for recurrent CDI compared to standard therapy? Does effectiveness vary by method of transplantation?
KQ2 What is the effectiveness of fecal microbiota transplantation for refractory CDI compared to standard therapy? Does effectiveness vary by method of transplantation?
KQ3 What is the effectiveness of fecal microbiota transplantation as initial therapy for CDI compared to standard therapy? Does effectiveness vary by method of transplantation?
KQ4 What are the harms of fecal microbiota transplantation therapy compared to standard therapy for initial, recurrent, or refractory CDI? Do the harms vary by method of transplantation?
KQ5 Is the procedure acceptable to patients? Does patient acceptability vary by method of transplantation?