# EVIDENCE TABLES

Appendix C, Table 1 Study Characteristics

Appendix C, Table 2 Outcomes after Initial Transplant and Adverse Events

Appendix C, Table 3 Outcomes after Repeat Transplant