# SEARCH STRATEGY

## Database: Ovid MEDLINE(R)

Search Strategy:

1. exp Feces/ or (fecal or faecal or feces or faeces or stool or microbiota).mp.
2. (donor or transplant$).mp. or exp Transplants/
3. 1 and 2
4. exp Clostridium Infections/ or exp Clostridium difficile/ or exp Enterocolitis, Pseudomembranous/ or (c difficile or c diff or clostridium difficile).mp.
5. 3 and 4
6. limit 5 to (english language and humans and yr=”1980 -Current”)