# SUMMARY AND DISCUSSION

This evidence synthesis summarizes the efficacy of family involved psychosocial treatments in improving the outcomes of patients with mental health conditions in the US since 1995. Two key questions were identified. Our search yielded 51 articles (39 trials), including trials of family interventions for substance use disorders (22 trials), bipolar disorder (6 trials), schizophrenia and related disorders (4 trials), PTSD (2 trials), sexual functioning disorders (2 trials), depression (1 trial), binge eating disorder (1 trial), and nicotine dependence (1 trial).

Overall, this review represents a variety of studies examining family involved treatments for mental health conditions. Trials were highly heterogeneous in terms of intervention characteristics, size, population, and findings. In many cases, the family intervention was manualized and withdrawals from the trials were adequately described. Typically, well-validated outcome measures were employed, diagnoses were verified by structured clinical interviews, and exclusion/inclusion criteria were clearly described. However, few studies included a description of allocation concealment or blinding procedures and measures used to assess the same construct were highly variable across trials. Frequently, intent to treat analyses were either not described or not employed, assessments of treatment integrity were frequently not described, and for many studies, samples were small and analyses underpowered. Additionally, many studies were conducted on mostly white and male samples, who were under 40 years old, and in all but two trials, Veteran status among participants was not reported. While post-treatment symptom severity was frequently reported, many of our other outcomes of interest were not. Most notable was the frequent absence of assessments of global family/couple adjustment, communication, conflict, observational family/ couple interactions, intimate partner violence, adherence, attendance, and satisfaction with care. The substance use literature posed the largest exception to this, with studies frequently examining global family/couple adjustment, adherence, attendance, and satisfaction with care. This likely reflects the more advanced stage of development of this literature.

The majority of studies fell into either Baucom and colleague’s9 disorder specific couple/family treatment and/or partner-assisted treatment categories. The purposes of family involvement also varied and included, but were not limited to, engaging patients in care, family members acting as out-of-session coaches, psychoeducation to improve family’s support for patients, and addressing family conflict that could exacerbate symptoms.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What is the efficacy of family involved interventions in improving outcomes for adult patients with mental health conditions [i.e., how do family involved psychosocial treatments compare to no psychosocial treatment: (a) waitlist/no treatment or (b) medication management only]?

The level of development of the evidence for family involved treatments varied greatly across conditions. Consequently, family treatments for some conditions had a number of efficacy trials prior to our search timeframe (i.e., schizophrenia and substance use disorder). For these conditions, the trials reviewed were more applicable to KQ2. See Table 1 for a review of the efficacy status of family treatments for mental health conditions prior to our review.

#### Substance Use Disorders

One trial64 found that among patients completing an inpatient alcohol detoxification program, a single family session and single family follow-up to help plan for continuing care (partner-assisted treatment9) did not result in significantly improved percent days abstinent post-intervention or greater attendance to continuing care. However, 92% of those receiving the family intervention were more likely to enter a continuing care program, a 30% improvement over patients hospitalized for substance use detoxification whose families did not participate in their aftercare planning.

#### Bipolar Disorder

Two trials compared a family intervention to a drug-only treatment. In one trial medication management alone was compared to medication management plus either Problem Centered Systems Therapy of the Family (PCSTF; a general family therapy9) or psychoeducational multifamily groups (a disorder specific family intervention9). There were no differences in symptoms between either family involved treatments or medication management alone.89, 97, 98 However, compared to medication management only, patients from distressed families reported significantly lower rates of depressive episodes (psychoeducational multifamily groups: 1.4 fewer episodes per year, d = 1.0; PCSTF: 0.9 fewer episodes, d = 0.70), shorter duration of depressive episodes (psychoeducational multifamily groups: 14% less time; d = 0.82), and fewer mood episodes (psychoeducational multifamily groups: 1.7 fewer episodes, yearly, d = 0.82), suggesting a family intervention specific to bipolar disorder or a general family therapy could provide improved treatment response for patients with bipolar disorder in distressed families. In the other trial, while those assigned to psychoeducational maritial therapy (a disorder specific couple intervention) did not report greater symptom relief than those assigned to medication management only, patients in marital therapy did report better global functioning (7 points on the 100 point GAS) and medication adherence (0.53 points on a 6 point scale) than those assigned to medication management only.94 In both cases, family functioning outcomes were not reported.

#### Schizophrenia

No trials.

#### PTSD

One trial demonstrated exposure plus Behavioral Family Therapy (a disorder specific family therapy9) resulted in better PTSD outcomes than waitlist;8 however these differences eroded at follow-up and drop out was worse among those in the family treatment condition. Another trial demonstrated significantly better engagement in treatment for the patients (Bosnian refugees) of those who participated in family support groups (CAFES; a trauma-specific family therapy), than waitlist.105 Specifically, patients’ whose family members participated in CAFES attended 4 more mental health visits than waitlist controls.

#### Sexual Functioning

One trial106 found subjects assigned to sex therapy plus medication reported greater satisfaction with treatment than those assigned to medication alone (disorder specific couple treatment).9, 106 Differences between conditions on erectile functioning up to two months after treatment were not significant. A second trial found no significant difference between those assigned to four weeks of cognitive-behavior sex therapy plus medication versus those assigned to medication alone after 4 weeks of treatment. Further descriptive statistics on differences between the two groups were provided at this post-treatment assessment but further formal testing was not provided.

#### Other Conditions Examined in Single Trials

One small trial of brief couple therapy for depression (n = 35; disorder specific couple treatment) found that couple therapy led to significantly improved depression symptoms and marital satisfaction. On continuous measures, scores on the BDI-II (d = 0.54), HAM-D (d = 0.72), and DAS (d = 0.43) were each significantly improved for participants in couple therapy compared to waitlist controls.114 A trial of group CBT for binge eating disorder found that CBT with or without spouse involvement resulted in better symptom improvement than waitlist.115

### Key Question #2 What is the effectiveness of family involved interventions compared to alternative interventions in improving outcomes for adult patients with mental health conditions [i.e., how do family involved interventions compare to (a) any individually-oriented psychosocial intervention or (b) any alternative family involved intervention]?

#### Substance Use Disorders

Twenty-one of 22 trials addressed KQ2. Fifteen trials compared family treatment to individually- oriented treatment as usual or manualized individual behavior therapy (13 of these trials examined BCT or BFT for an alcohol or substance use disorder; 2 trials examined alternative methods of family involvement in care) and 6 trials compared a family treatment to an alternative family involved treatment (3 trials examined CRAFT, a disorder-specific and partner-assisted treatment; 3 examined BCT or BFT). Findings are summarized by intervention below.

##### Behavioral Couple Therapy or Behavioral Family Therapy (disorder specific couple therapy9)

[underlined: Effects on substance use]. BCT participants used substances for 1.2 fewer days per month (14.6 per year) at post-treatment, 3.3 days per month (40 per year) at 6 months, and 3.6 days per month (44 per year) for 12 month follow-ups. This same general pattern of results was found for studies addressing drug use only, alcohol use only, drug use disorders among men, and drug use disorders among women.

[underlined: Effects on relationship adjustment]. Better relationship adjustment following treatment was found among those assigned to BCT than ICBT, with 12.5% higher scores on the DAS, on average, among those who participated in BCT, one year after treatment.

[underlined: Therapy with non-intimate partners (BFT)]. Findings are mixed for differences between ICBT and BFT, a version of BCT including non-intimate partners, with one trial finding no differences in substance use between BFT and individual treatment and a second trial finding significantly lower rates of substance use among those in BFT than those in individual treatment at 18 months after treatment (13.2% fewer days abstinence). However, these differences eroded at 30 month follow-ups.

[underlined: Brief BCT]. Two trials examined both a brief version of BCT and standard BCT for substance use disorders and found both BCT and brief BCT led to significant differences in PDA compared to ICBT, but few differences were found between the standard and brief versions of BCT.

[underlined: BCT with relapse prevention]. Two trials added a relapse prevention intervention to BCT (2 trials4, 72, 86, 87) with one trial finding no differences between conditions72, 86, 87 and the other finding greater reductions in substance use, with 13.2% fewer days of use 18 months after treatment.4 These differences eroded and were non-significant at the 30 month follow-up. In this trial, the benefits of BCT with relapse prevention were strongest for those in the most distressed relationships and with the most severe drinking behavior.4

[underlined: Same sex couples]. One trial compared BCT to ICBT with same sex couples, finding fewer percent days heavy drinking among BCT participants at long term follow-ups and significantly slower rates of erosion in treatment effects among BCT participants (i.e., BCT participants were slower to increase their rates of heavy drinking than ICBT patients after treatment).

[underlined: Veterans]. Two studies examined Veterans with alcohol use disorders.4, 65 One found no difference between BCT and a general couple therapy on sexual satisfaction.65 Rates of substance use after treatment were not reported. The second compared BCT to BCT with relapse prevention, discussed above.4 Veterans participating in BCT4 demonstrated comparable or better rates of PDA from alcohol use (post-treatment: 98.0%; short-term follow-up: 87.6%; long-term follow-up: 82.7%) than average rates of PDA reported in the AUD trials included in our pooled analyses. However, direct comparisons within trials between Veteran and non-Veteran have yet to be conducted, and research has yet to evaluate BCT compared to individual therapy among Veteran samples.

##### CRAFT (disorder-specific and partner-assisted treatment9)

Across 3 trials80, 81, 83 CRAFT was found to be superior to alternative family treatments in improving patients’ initiation of substance use treatment 30–48%. Trials did not provide data on differences in overall rates of session attendance or substance use.

##### Alternatives to BCT and CRAFT

[underlined: BCT versus non-disorder specific couple therapy]. Two trials compared BCT to an alternative non-disorder specific couple treatment65, 73 finding no differences between the couple interventions on substance use73 or relationship functioning.65, 73

[underlined: Adding additional treatment components to BCT]. One trial added parenting skills training to BCT71 and a second added attendance to AA and Al-Anon.72, 86, 87 Both trials found no differences in symptoms or couple functioning between BCT with additional treatment components versus standard BCT.

[underlined: Reciprocal relationship counseling]. Carroll77 found that the combination of reciprocal relationship counseling (disorder specific intervention9), contingency management, and naltrexone use was superior to contingency management plus naltrexone only in family functioning, but not in percent days abstinent or days in treatment.

[underlined: Motivational and psychoeducational treatment with couple counseling for heroin users with pregnant partners]. Jones and colleagues70 found that subjects in a motivational and psychoeducational intervention that included couple therapy for male heroin users with pregnant intimate partners, actually had [underlined: higher] heroin use at short-term follow up, compared to an individual only counselor-led drug treatment support group.

#### Bipolar Disorder

Five RCTs provided data relevant to KQ2.

##### Family-Focused Therapy (FFT; 4 trials; disorder specific family treatment9)

- FFT or an adapted version of FFT (FFT-HPI93) led to better symptom response than either individually-oriented care (1 trial91) or alternative family involved interventions (2 trials90, 93).
  □ FFT leads to lower rates of relapse than crisis management with limited family involvement, 24 months after randomization (35% relapse versus 54%). Patients in crisis management relapsed an average of 20 weeks sooner than those in FFT.5, 90
  □ FFT leads lower rates of relapse (28% versus 60%) and lower rates of hospitalization (12% versus 60%) than individual therapy one year after the end of active treatment.91
  □ No significant differences were found between FFT and individual therapy on medication adherence.91
  □ FFT-HPI leads to fewer manic (4.2 points on the YMRS; d = 0.34; small effect) and depression symptoms (5.6 points on the HAM-D; d = 0.67; medium effect) among bipolar patients than health education provided to families via DVDs.93
- One trial92 found no significant differences in symptoms of bipolar disorder or family functioning between FFT and either cognitive behavioral therapy or interpersonal and social rhythm therapy, suggesting FFT may perform similarly to other empirically supported, highly intensive interventions in improving symptoms of bipolar disorder.
- Mixed findings limit conclusions that can be drawn about the role of FFT in session attendance or medication adherence.

##### Disorder Specific versus General Family Therapy (1 trial89, 97, 98)

The difference in rates of recovery between general family therapy and disorder specific family therapy, delivered in multiple family groups, were non-significant.

#### Schizophrenia

Three trials addressed KQ2 (1 trial for KQ1 and 3 for KQ2 due to greater than 2 comparison conditions).

##### Multiple Family Groups (MFG; 1 trial)101–103

- One trial compared MFGs (disorder specific family therapy 9), an interventions focused on psychoeducation, family functioning, and social support, to individually oriented psychosocial intervention. Results indicated that, at the one year point of a two year intervention, MFGs improved negative symptoms of schizophrenia (e.g., blunted affect, alogia, anhedonia, inattention, avolition) an average of one point on a 25 point scale and led to 12% lower rates of hospitalization at state level psychiatric hospitals than individual treatment.
- Differences in rates of hospitalization overall or at non-state level facilities, or use of crisis care, were non-significant at post-treatment and one year after treatment.

##### Assertive Community Treatment (ACT) With and Without a Biweekly Multi-Family Group (1 trial29)

- No significant differences were found between groups on hospital admissions, symptoms, or family outcomes.
- Employment rates for ACT and multifamily groups were significantly different during treatment but non-significant at the final follow-up.

##### Applied Family Management (AFT; 1 trial104)

- Non-significant differences were found between intensive and less intensive family interventions in symptoms or rates of hospitalization. Authors note group differences may have limited clinical significance.104
- A more intensive family therapy (AFM) improved family functioning (patient rejection scale) by 0.32 scale points at 1 year (medium effect size, 0.31) and 1.03 scale points (medium effect size, 0.30 effect size) at 2 year follow-up, over less intensive family interventions.

##### Family Intervention for Dual Disorders (1 trial; disorder specific family treatment9)

- Subjects with a comorbid substance use disorder and serious mental illness (e.g., schizophrenia, bipolar disorder) demonstrated greater improvements in psychiatric symptoms (BPRS psychosis, medium effect size, 0.32; BPRS total, small effect size, 0.17) when assigned to a longer term (9–18 months) psychoeducational family program than a brief (2–3 month) family intervention.100
- Differences in substance use and global functioning across conditions were non-significant

#### PTSD

One trial found no significant differences in PTSD outcomes between exposure therapy with Behavioral Family Therapy (disorder specific family intervention9) versus exposure therapy only,8 however the family involved arm resulted in poorer rates of dropout than exposure alone.

#### Sexual Functioning

No trials.

#### Other Conditions Examined In Single Trials

There were no differences between family involved interventions and individually-oriented treatments in one trial examining smoking cessation in pregnant women118 and a second examining binge eating disorder, with the exception of greater agreement between spouses regarding a plan of action for binge eating.115

## EFFICACY

In Table 16 below, we summarize the efficacy status23 and strength of evidence62 for outcomes of interest (i.e., symptoms, family/couple functioning, and, in some cases, treatment engagement) for those family treatments demonstrating benefits over their comparators that met our review criteria. In three cases, studies demonstrated an individually-oriented, disorder specific intervention plus a family intervention led to greater improvements than waitlist/drug only conditions, but the combined treatment did not demonstrate significant gains over the individually-oriented treatment alone in the same trial.8, 77, 115 Consequently, these trials are not included in the table below. These findings represent only studies performed in the US in the last 15 years that report on patient outcomes. Studies finding no significant differences between the treatment and the comparator at post-treatment or follow-up assessments on our outcomes of interest are not included as ‘possibly efficacious studies’ and, consequently, not incorporated.

Table 16 Family Interventions since 1996 that Improve Outcomes for US Patients with Mental Health Conditions

MH Condition | Intervention | Comparator | Outcome | Efficacy Status | Strength of Evidence
Alcohol Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 1) Substance Use | 1 | Moderate^a^
Alcohol Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 2) Relationship Adjustment | 1 | Moderate^a^
Alcohol Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 3) Intimate Partner Violence | 3 | Low
Alcohol Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 4) Attendance | 3 | Low
Alcohol Use Disorders
Alcohol Use Disorders | Brief family intervention to promote continuing care64 | Treatment-as-usual | 1) Substance Use | ND | Low
Alcohol Use Disorders | Brief family intervention to promote continuing care64 | Treatment-as-usual | 2) Treatment Initiation | 3 | Low
Alcohol Use Disorders
Alcohol Use Disorders | Behavioral Couple Therapy + relapse prevention64 | Behavioral Couple Therapy | 1) Substance Use | 3 | Low
Alcohol Use Disorders | Behavioral Couple Therapy + relapse prevention64 | Behavioral Couple Therapy | 2) Relationship Adjustment | ND | Low
Alcohol Use Disorders
Alcohol Use Disorders | Behavioral Family Treatment82 | Individual Behavioral Therapy | 1) Substance Use | 3 | Low
Alcohol Use Disorders | Behavioral Family Treatment82 | Individual Behavioral Therapy | 2) Family Functioning | ND | Low
Alcohol Use Disorders
Alcohol Use Disorders | CRAFT81 | Alternative Family Treatments | 1) Substance Use | ND | Low
Alcohol Use Disorders | CRAFT81 | Alternative Family Treatments | 2) Family Functioning | ND | Low
Alcohol Use Disorders | CRAFT81 | Alternative Family Treatments | 3) Treatment Initiation | 3 | Low
Drug Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 1) Substance Use | 1 | Moderate^a^
Drug Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 2) Relationship Adjustment | 1 | Moderate^a^
Drug Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 3) Intimate Partner Violence | 3 | Low
Drug Use Disorders | Behavioral Couple Therapy | Individual Behavioral Therapy | 4) Attendance | 1 | Low^b^
Drug Use Disorders
Drug Use Disorders | Behavioral Family Treatment68, 82 | Individual Behavioral Therapy | 1) Substance Use | 3 | Low
Drug Use Disorders | Behavioral Family Treatment68, 82 | Individual Behavioral Therapy | 2) Family Functioning | 3 | Low
Drug Use Disorders
Drug Use Disorders | CRAFT80, 83 | Al-Anon/Nar-Anon | 1) Substance Use | ND | Moderate
Drug Use Disorders | CRAFT80, 83 | Al-Anon/Nar-Anon | 2) Family Functioning | ND | Low
Drug Use Disorders | CRAFT80, 83 | Al-Anon/Nar-Anon | 3) Treatment Initiation | 1 | Moderate
Bipola | Family-Focused Treatment-Health Promoting Intervention93 | Health information DVDs reviewed by caregivers | 1) Symptoms | 3 | Low
Bipola
Bipola | Family-Focused Treatment | Crisis management with two in-home family psychoeducation sessions5, 90 | 1) Symptoms | 3 | Low
Bipola | Family-Focused Treatment | Crisis management with two in-home family psychoeducation sessions5, 90 | 2) Medication Adherence | 3 | Low
Bipola | Family-Focused Treatment
Bipola | Family-Focused Treatment | Problem-focused, psychoeducational Individual therapy91 | 1) Symptoms | 3 | Low
Bipola | Family-Focused Treatment | Problem-focused, psychoeducational Individual therapy91 | 2) Medication Adherence | ND | Low
Bipola | Family-Focused Treatment
Bipola | Family-Focused Treatment | Cognitive behavior therapy92,95 | 1) Symptoms | ND | Low
Bipola | Family-Focused Treatment
Bipola | Family-Focused Treatment | Interpersonal and social rhythm therapy92, 95 | 1) Symptoms | ND | Low
Bipola
Bipola | Marital intervention + medication94 | Medication only | 1) Symptoms | ND | Low
Bipola | Marital intervention + medication94 | Medication only | 2) Global Functioning | 4 | Low
Bipola | Marital intervention + medication94 | Medication only | 3) Medication Adherence | 4 | Low
Schizophrenia | Multiple Family Groups101–103 | Standard, Individually-oriented care | 1) Symptoms | ND | Low
Schizophrenia | Multiple Family Groups101–103 | Standard, Individually-oriented care | 2) Any Hospitalization | ND | Low
Schizophrenia | Multiple Family Groups101–103 | Standard, Individually-oriented care | 3) State Hospitalization | 3 | Low
Schizophrenia | Multiple Family Groups101–103 | Standard, Individually-oriented care | 4) MH Care Utilization | ND | Low
Schizophrenia
Schizophrenia | Family intervention + in home behavioral family therapy (Applied Family Management24, 104 | Family intervention | 1) Symptoms | ND | Low
Schizophrenia | Family intervention + in home behavioral family therapy (Applied Family Management24, 104 | Family intervention | 2) Family Functioning | ND | Low
Schizophrenia | Family intervention + in home behavioral family therapy (Applied Family Management24, 104 | Family intervention | 3) Patient Rejection by Family | 3 | Low
Schizophrenia | Family intervention + in home behavioral family therapy (Applied Family Management24, 104 | Family intervention | 4) MH Care Utilization | ND | Low
Schizophrenia | Family intervention + in home behavioral family therapy (Applied Family Management24, 104 | Family intervention | 5) Attendance | ND | Low
Schizophrenia & Substance Use Disorder | Psychoeducation + skills oriented training ( Family Intervention for Dual Disorder99, 100 | Short term psychoeducation | 1) Schizophrenia Symptoms | 3 | Low
Schizophrenia & Substance Use Disorder | Psychoeducation + skills oriented training ( Family Intervention for Dual Disorder99, 100 | Short term psychoeducation | 2) Substance Use | ND | Low
Schizophrenia & Substance Use Disorder | Psychoeducation + skills oriented training ( Family Intervention for Dual Disorder99, 100 | Short term psychoeducation | 3) Global Functioning | 3 | Low
Schizophrenia & Substance Use Disorder | Psychoeducation + skills oriented training ( Family Intervention for Dual Disorder99, 100 | Short term psychoeducation | 4) Medication Adherence | ND | Low
PTSD | Coffee and Family Education and Support105 | Waitlist | 1) Number of MH Visits | 4 | Low
Depression | Brief problem-focused couple therapy114 | Waitlist | 1) Symptoms | 4 | Low
Depression | Brief problem-focused couple therapy114 | Waitlist
Depression | Brief problem-focused couple therapy114 | Waitlist | 2) Relationship Adjustment | 4 | Low

Efficacy Status:

1 = Efficacious & Specific = superior to placebo, nonspecific, or alternative intervention in at least two studies conducted by independent research teams.

2 = Efficacious; superior to waitlist in RCTs conducted by two independent research teams.

3 = Possibly Efficacious & Specific; criteria met for efficacious and specific from a single study.

4 = Possibly Efficacious; criteria met for efficacious from a single study (Baucom, 1998;9 Chambless & Hollon,1998^23^)

ND = No significant differences found; MH = Mental health

Strength of Evidence:

High = High confidence evidence reflects true effect. The effect and confidence in the estimate of effect is unlikely to change with further research.

Moderate = moderate confidence that evidence reflects true effect. The effect and confidence of the effect may change with further research.

Low = Low confidence evidence reflects true effect. The effect and confidence of the effect will likely change with further research.62

a Seven of the nine trials comparing these conditions were written by or based on data collected by Dr. Fals-Stewart. See Substance Use Disorders Results for KQ2 for discussion.

b Several studies also found non-significant differences, leading to low strength of evidence.

## STRENGTH OF EVIDENCE

In addition to identifying studies that have demonstrated efficacy or are possibly efficacious, we rated the confidence with which we draw these conclusions for the outcomes of interest (i.e., the ‘strength of the evidence that underlies conclusions,’ p. 513, Owens et al.62). Strength of evidence was considered by mental health condition, given the wide variety of interventions, techniques, and treatment targets of these interventions. In general, with the exception of behavioral couple therapy for SUDs, CRAFT for increasing treatment initiation among patients with SUDs, and Family Focused Therapy (FFT) for bipolar disorder, each intervention was typically examined in one or two trials. Additionally, the FFT studies contained highly diverse sets of comparison conditions and findings were largely mixed, limiting our confidence in the strength of evidence across these trials.

Several of the individual trials were of good or fair quality (low or medium risk of bias) but with a single, often small trial of a particular intervention for a particular outcome and imprecise estimates of effect, we have low confidence that the available evidence for the interventions examined in single trials reflect the true effect. As such, the strength of evidence for any given intervention, with the exception of BCT for drug use disorders and CRAFT for increasing treatment initiation among those with an SUD, is generally low. Specific ratings for treatments deemed efficacious or possibly efficacious are presented in Table 16. Importantly, our strength of evidence ratings are based solely on the results of our search, which included only US studies of family involved psychosocial treatments for mental health conditions since 1995 that included patient outcomes. Also, this Table should be considered in tandem with Table 1, which identifies those interventions established as efficacious [underlined: prior] to our review, including behavioral family therapy and supportive family therapy for schizophrenia.6, 9

## CONCLUSIONS

Nearly half of the trials we located were examinations of family involved treatments for substance use disorders, typically BCT or BFT for substance use disorders (disorder specific couple or family therapy9). While findings were not without contradiction, behavioral couple therapy is superior to individual behavior therapy for improving substance use and relationship distress. CRAFT81, 83 also increases the rates with which patients with substance use disorders initiate substance use treatment. Mixed findings indicate relapse prevention added to behavioral couple therapy may improve outcomes, especially among those with the most severe substance use and relationship distress. Finally, unlike other mental health conditions, two trials were conducted with Veterans,4, 65 but only one trial reported substance use outcomes and compared BCT to BCT with relapse prevention (O’Farrell, 1998a), making it difficult to draw conclusions about whether Veteran samples achieve the same benefits from BCT as other samples. More research is clearly needed examining the efficacy of family involved treatments with Veteran samples.

Findings for bipolar disorder were also mixed, with single trials demonstrating family therapy improves symptoms over medication management alone, particularly for those in distressed families, and FFT improves symptoms over alternative treatment approaches in two trials, but performs similarly to other empirically supported, individually-oriented interventions in another trial. Specifically, 1) FFT or an adapted version of FFT (FFT-HPI93) led to greater symptom improvements than either an individually-oriented treatment (1 trial91) or alternative family involved interventions (2 trials90, 93), 2) FFT performed similarly to other empirically supported, highly intensive, individually-oriented interventions in improving symptoms of bipolar disorder,92 3) for patients in distressed families, improved symptoms of depression were found for those in either a disorder specific multifamily group or general family therapy than medication management alone,98 and 4) marital psychoeducational therapy led to greater improvements in global functioning and medication adherence, but not in symptoms, than medication management alone.

Work conducted prior to the time frame of our review has established the efficacy of behavioral family therapy and supportive family therapy for schizophrenia.9 Given the wealth of data prior to 1996 supporting these interventions for schizophrenia, we were surprised to find only 4 US trials since that time. These trials expanded upon the work conducted in prior studies by including complex cases (i.e., multiple diagnoses or problems), but provided limited additional clarity regarding which family treatments enhance patient outcomes or if family treatments improve outcomes outside of relapse/rehospitalization rates. As noted in previous reviews,9 schizophrenia and bipolar disorders are chronic, lifelong illnesses. Consequently, appropriate outcomes include lengthening time to relapse, improving quality of life, and enhancing family functioning, rather than success in eliminating or ‘curing’ symptoms. Among our outcomes of interest, one trial found rates of state-hospitalization were lower among those in multiple family psychoeducational groups than those in a shorter individually-oriented intervention of psychoeducation only.103 A second trial found no differences on our outcomes of interest at final follow-ups for those participating in Assertive Community Training with or without a biweekly multiple family group.29 A third trial found family therapy with an in home behavioral family therapy component resulted in less patient rejection by families than the same intervention without in-home behavioral family therapy. Differences on symptoms and rates of hospitalization were non-significant. A final trial demonstrated greater improvements in symptoms of serious mental illness and functioning, but not lower substance use, among dually diagnosed patients (serious mental illness and SUDs) assigned to a 9–18 month psychoeducational family program versus a brief (2–3 month) family intervention. However, problems with recruitment and retention of these complex patients raises concerns about the feasibility of family treatment for this group, especially long-term interventions.100 Additional evidence from non-US trials exists supporting family treatments for schizophrenia for the prevention or delay of relapse over the past 15 years and was not included in the present review. The applicability of results to US Veterans and even US patients from studies outside the United States, particularly in China, is limited. A recent, more inclusive review of family treatments for schizophrenia concluded the quality of reporting in most these studies was poor.126

Family treatments for a number of additional mental health conditions were examined in one or two trials, including PTSD (2 trials), erectile dysfunction (2 trials), depression (1 trial), binge eating disorder (1 trial), and smoking cessation (1 trial). A family support group to encourage treatment engagement among Bosnian refugees with PTSD found greater rates of engagement than waitlist only participants (one trial). Additionally, support was found for brief couple therapy for depression over waitlist in improving depression and couple functioning. Results from the remaining trials included largely non-significant differences between family treatments and either individual treatment (PTSD, binge eating, smoking) or, for erectile dysfunction, medication management.

Overall, the literature indicated family involved treatments for mental health conditions were as effective as or more effective than individually-oriented psychotherapies, with two exceptions. The addition of approximately 23 weeks of disorder-specific behavioral family therapy after 9 weeks (18 sessions) of exposure therapy for PTSD lead to greater rates of treatment dropout than exposure therapy alone or waitlist.8 Additionally, male opiod users with pregnant female partners who participated in a combination of motivational enhancement, case management, contingency management, and psychoeducational couple therapy reported greater heroin use at short-term follow-ups than patients participating in usual care. Outside of these two trials, findings either favored family involvement or demonstrated no significant differences between family interventions and comparator conditions, even when comparators were robust, active individually-oriented interventions. However, outside of the SUD literature, the number of trials testing the same intervention with the same or similar comparators was limited, leading to low confidence in the consistency of these conclusions. Additionally, many studies did not evaluate family and couple functioning after treatment, treatment adherence, or satisfaction with care. Additionally, most studies did not report Veteran status of their participants. Consequently, while the present study sought to optimize the relevance of this review to Veterans by examining only US studies, the generalizability of findings from these trials to Veterans’ samples is largely unknown.

## LIMITATIONS

There were several important limitations to this review. First, in order to focus on recent, high quality studies, most applicable to Veterans, our review was limited to randomized controlled trials conducted over the last 15 years. As discussed above, some family interventions were established as efficacious prior to this time frame, limiting the need for, and consequently, volume of studies addressing KQ1. Secondly, this review was also limited to studies conducted in the US only. The efficacy of family interventions has been established in many studies internationally (i.e. in China for family treatments for serious mental illness), however, their applicability to the US Veteran population or US healthcare system is not known.129 Third, developing and advancing a psychosocial intervention such that it is appropriate for testing in an RCT is a major task requiring years of work and even further complicated by the need to recruit both patients and their families for participation. Consequently, there are numerous family involved interventions not included in our review that are in various stages of development or are currently under evaluation in RCTs (e.g., Couple therapies for PTSD,139 Family Member Provider Outreach Program,140 Coaching into Care,141 REACH142). While our focus on RCTs is warranted, given the VA’s need for direction on which family interventions have established an evidence base, exclusions of these interventions under development is a potential limitation. Fourth, we elected to organize our findings by mental health condition, consistent with the organization of the DSM-IV. However, alternative methods of presenting findings exist. Findings could be presented comparing ‘serious mental illness’ (i.e., discussing schizophrenia and bipolar trials together) to other forms of mental illness or by type of intervention (family versus couple; disorder specific versus general family therapies; interventions using similar approaches, such as psychoeducational interventions). Conclusions using these alternative approaches to synthesizing findings would likely differ from those reached in this review.

Finally, interventions specifically targeting caregiver outcomes are important. However, given the VA’s traditional focus on Veteran outcomes, our review included only studies which assessed participants’ outcomes (including family and couple functioning). Interventions that solely seek to improve the distress and burden experienced by family members of those with mental illness are were not reviewed, and rates of improvement in the personal distress experienced by family members or caregivers were not included when reported in the trials reviewed. Our findings cannot speak to the efficacy of family interventions for mental health conditions in improving the functioning of patient’s family members and caregivers.

## RECOMMENDATIONS FOR FUTURE RESEARCH

There are a number of important gaps in our findings that highlight the need for future work. As discussed above, further work is needed to integrate our findings on patient outcomes with research examining how family/couple interventions effect outcomes for spouses and other family members (i.e., caregiver burden, distress, anxiety, etc). For substance use disorders, further work is needed establishing that patients’ whose families participate in CRAFT have better reductions in substance use and better longer-term retention in treatment than those assigned to other interventions. Additionally, comparisons between BCT and other family involved interventions are warranted. Finally, a large number of the BCT trials reviewed were conducted within a single lab (i.e., Dr. Fals-Stewart) and further work outside of this laboratory is indicated.

A few trials found family interventions were most effective (i.e., resulted lower rates of symptoms) than comparison conditions for patients in distressed families and/or with more severe baseline symptoms (i.e., BCT with relapse prevention and family therapy for bipolar disorder). Family distress by condition interactions have also been found in studies of depression conducted prior to our review, suggesting that individuals benefit more from individual than marital therapy when in non-distressed relationships.44, 137 If replicated, these findings could have important implications to personalizing treatment for those with greater family distress and/or more severe symptoms of mental illness. Future work should continue to test for these interactions.

With the exception of two interventions, BCT for substance use and CRAFT for the initiation of substance use treatment, in the past fifteen years, very few family treatments for improving adult mental health conditions have been investigated in more than one rigorous RCT in the US. Generally, the literature is in need of this work. Future trials are needed examining CRAFT, BCT, and Family-Focused Therapy specifically in Veteran samples. Additionally, further work is needed to continue to establish the efficacy of interventions highlighted in Table 15 as possibly efficacious as they have demonstrated some significant improvements in patient functioning over comparison conditions in at least one trial (rated 3 or 4 on the status of their efficacy). This includes further trials of relapse prevention in addition to BCT, CRAFT for alcohol use disorders, brief BCT for substance use disorders, BFT (with non-intimate partners) for substance use disorders, family involvement to increase treatment initiation among patients hospitalized for substance use detoxification, Family-Focused Treatment-Health Promoting Intervention for bipolar disorder, Family Focused Treatment for bipolar disorder, marital therapy for bipolar disorder, in home behavioral family therapy as an addition to family treatments for schizophrenia, combined treatments for co-occurring schizophrenia and substance use disorders (Family Intervention for Dual Disorder), and support groups to promote treatment use among patients with PTSD (CAFES). Such trials are needed that use large samples, longer-term follow-ups, high quality methodologies, evaluate both patient and family outcomes, compare outcomes by ‘type’ of family member included (e.g., spouse, parent, sibling), and use standardized symptom measures that can facilitate comparisons across trials.

Evaluating applications of these interventions to patients with comorbid conditions (e.g., substance use and serious mental illness), non-white samples, older patients (i.e., over 65), and Veteran groups is warranted. Additionally, alternative types of family constellations (i.e., close friends, same sex couples) have received little attention among existing RCTs. For Veterans, preferences for which family members to include (i.e., intimate partners versus other family members), how these preferences vary by era (i.e., recently returning Veterans versus Vietnam/ Korean War Veterans eras), and the availability and “type” of family members interested in participating (i.e., intimate partners versus other family members) is important to inform policy decisions, especially considering that current eligibility criteria for VA family-related services does not extend to close friends or intimate partners who do not reside with the Veteran. Additionally, research is needed evaluating methods of engaging families in care. This was demonstrating in a study of schizophrenia finding that 80% of families did not participate in optional follow up family group sessions.99, 100 Additionally, trials of family interventions for several mental health conditions were notably limited or absent from the published literature in the US in the past 15 years, including studies of family treatments for depression, PTSD and other anxiety disorders, personality disorders, eating disorders, and sexual functioning disorders, warranting further work with these conditions.

Given the intent of the ESP is to provide an objective, non-biased approach to the review topic, providing our own cost-benefit analysis of interventions is beyond scope of this review. Additionally, this information was largely absent from RCTs reviewed. Consequently, future research is needed evaluating the costs and benefits of effective interventions. This work could further consider multifamily versus single family interventions for schizophrenia, intensive versus less intensive interventions for serious mental illness, and brief versus standard length interventions for substance use and other disorders (e.g., standard BCT versus brief BCT).

Finally, with the exception of a few studies within the schizophrenia literature, limited attention was paid among studies reviewed to interventions for patients with multiple diagnoses, conditions, or problems. Future research should work to identify efficacious family treatments for patients with commonly co-occurring conditions important to VA populations, such as PTSD and substance use disorders, serious mental illness and substance use disorders, comorbid personality disorders among patients seeking treatment for an Axis I condition. Patients were not excluded from trials due to diagnosis of a personality disorder, but findings were typically not stratified by other co-morbid conditions, preventing comparisons of treatment response by co-morbid conditions. Additionally, in the substance use literature, couples and families in which both the patient and the family member have a substance use disorder are typically excluded from trials. However, in practice, dual SUD couples and family members are not uncommon. Further work is also needed to identify evidence based practices and approaches to family involvement for patients with co-occurring intimate partner violence, suicidality, self-injury, or/ or traumatic brain injury.