# REFERENCES

1 Milliken CS, Auchterlonie JL, Hoge CW. Longitudinal assessment of mental health problems among active and reserve component soldiers returning from the Iraq war. JAMA. Nov. 14. 2007;298(18):2141-8. [pmid: 18000197].
2 Meis LA, Erbes CR, Polusny MA, et al. Intimate relationships among returning soldiers: the mediating and moderating roles of negative emotionality, PTSD symptoms, and alcohol problems. J Trauma Stress. Oct. 2010;23(5):564-72. [pmid: 20848617].
3 Bodenmann G, Plancherel B, Beach SR, et al. Effects of coping-oriented couples therapy on depression: a randomized clinical trial. J Consult Clin Psychol. Dec. 2008;76(6):944-54. [pmid: 19045963].
4 O’Farrell TJ, Choquette KA, Cutter HS. Couples relapse prevention sessions after behavioral marital therapy for male alcoholics: outcomes during the three years after starting treatment. J Stud Alcohol. Jul. 1998;59(4):357-70. [pmid: 9647418].
5 Miklowitz DJ, George EL, Richards JA, et al. A randomized study of family-focused psychoeducation and pharmacotherapy in the outpatient management of bipolar disorder. Arch Gen Psychiatry. Sep. 2003;60(9):904-12. [pmid: 12963672].
6 Dixon LB, Lehman AF. Family interventions for schizophrenia. Schizophr Bull. 1995;21(4):631-43. [pmid: 8749890].
7 Bryne M, Carr A, Clark M. The efficacy of couples-based interventions for panic disorder with agoraphobia. J Fam Ther. 2004;26:105-25.
8 Glynn SM, Eth S, Randolph ET, et al. A test of behavioral family therapy to augment exposure for combat-related posttraumatic stress disorder. J Consult Clin Psychol. Apr. 1999;67(2):243-51. [pmid: 10224735].
9 Baucom DH, Shoham V, Mueser KT, et al. Empirically supported couple and family interventions for marital distress and adult mental health problems. J Consult Clin Psychol. Feb. 1998;66(1):53-88. [pmid: 9489262].
10 DiMatteo MR. Social support and patient adherence to medical treatment: a meta-analysis. Health Psychol. Mar. 2004;23(2):207-18. [pmid: 15008666].
11 Sellwood W, Tarrier N, Quinn J, et al. The family and compliance in schizophrenia: the influence of clinical variables, relatives’ knowledge and expressed emotion. Psychol Med. Jan. 2003;33(1):91-6. [pmid: 12537040].
12 Butzlaff RL, Hooley JM. Expressed emotion and psychiatric relapse: a meta-analysis. Arch Gen Psych. Jun. 1998;55(6):547-52.
13 Miklowitz DJ, Goldstein MJ, Nuechterlein KH, et al. Family factors and the course of bipolar affective disorder. Arch Gen Psych. Mar. 1988;45(3):225-31.
14 Hooley JM, Gotlib IH. A diathesis-stress conceptualization of expressed emotion and clinical outcome. Appl Prev Psychol. 2000;9:131-51.
15 Tarrier N, Sommerfield C, Pilgrim H. Relatives’ expressed emotion (EE) and PTSD treatment outcome. Psychol Med. Jul. 1999;29(4):801-11. [pmid: 10473307].
16 Miklowitz DJ. The role of family systems in severe and recurrent psychiatric disorders: a developmental psychopathology view. Dev Psychopathol. Summer. 2004;16(3):667-88. [pmid: 15605631].
17 Wendel JS, Miklowitz DJ, Richards JA, et al. Expressed emotion and attributions in the relatives of bipolar patients: an analysis of problem-solving interactions. J Abnorm Psychol. Nov. 2000;109(4):792-6. [pmid: 11196006].
18 Monson CM, Taft CT, Fredman SJ. Military-related PTSD and intimate relationships: from description to theory-driven research and intervention development. Clin Psychol Rev. Dec. 2009;29(8):707-14. [pmid: 19781836].
19 Epstein EE, McCrady BS. Behavioral couples treatment of alcohol and drug use disorders: current status and innovations. Clin Psychol Rev. Sep. 1998;18(6):689-711. [pmid: 9779329].
20 Smith JE, Meyers RJ. Motivating substance abusers to enter treatment: Working with family members. New York. Guilford Press. 2005.
21 Monson CM, Fredman SJ, Dekel RD. Posttraumatic stress disorder in an interpersonal context. B JG, editor. Interpersonal Processes in the Anxiety Disorders: Implications for Understanding Psychopathology and Treatment. 2010:179-208.
22 Lutz ME. Sobering decisions: Are there gender differences?. Alcohol Treat Q. 1991;8:51-64.
23 Chambless DL, Hollon SD. Defining empirically supported therapies. J Consult Clin Psychol. Feb. 1998;66(1):7-18. [pmid: 9489259].
24 Schooler NR, Keith SJ, Severe JB, et al. Relapse and rehospitalization during maintenance treatment of schizophrenia. The effects of dose reduction and family treatment. Arch Gen Psych. May. 1997;54(5):453-63.
25 Falloon IR, Boyd JL, McGill CW. Family care of schizophrenia: A problem solving approach to the treatment of mental illness. New York. Guilford Press. 1984.
26 Tarrier N, Barrowclough C, Vaughn C, et al. Community management of schizophrenia. A two-year follow-up of a behavioural intervention with families. Br J Psychiatry. May. 1989;154:625-8. [pmid: 2597854].
27 Xiong W, Phillips MR, Hu X. Family-based intervention for shizophrenic patients in China. A randomised controlled trial. Br J Psychiatry. 1994;165(2):239-47. [pmid: 7953039].
28 Randolph ET, Glynn SM, Eth S, Paz GG, Leong GB, Shaner AL. Family therapy for schizophrenia: Two year outcome. Annual Meeting of the American Psychiatric Association. 1995 May. 1995. Miami, Florida.
29 McFarlane WR, Dushay RA, Stastny P, et al. A comparison of two levels of family-aided assertive community treatment. Psychiatric Services. Jul. 1996;47(7):744-50. [pmid: 8807689].
30 Leff J, Vaughn C. Expressed emotion in families: Its significance for mental illness. New York. Guilford Press. 1985.
31 Zhang M, Wang M, Li J, et al. Randomised-control trial of family intervention for 78 first-episode male schizophrenic patients. An 18-month study in Suzhou, Jiangsu. Br J Psychiatry Suppl. Aug. 1994;(24):96-102. [pmid: 7946238].
32 McFarlane WR, Lukens E, Link B, et al. Multiple-family groups and psychoeducation in the treatment of schizophrenia. Arch Gen Psych. Aug. 1995;52(8):679-87.
33 Hogarty GE, Anderson CM, Reiss DJ, et al. Family psychoeducation, social skills training, and maintenance chemotherapy in the aftercare treatment of schizophrenia. II. Two-year effects of a controlled study on relapse and adjustment. Environmental-Personal Indicators in the Course of Schizophrenia (EPICS) Research Group. Arch Gen Psych. Apr. 1991;48(4):340-7.
34 Sisson RW, Azrin NH. Family-member involvement to initiate and promote treatment of problem drinkers. J Behav Ther Exp Psychiatry. Mar. 1986;17(1):15-21. [pmid: 3700666].
35 Hunt GM, Azrin NH. A community-reinforcement approach to alcoholism. Behav Res Ther. Feb. 1973;11(1):91-104. [pmid: 4781962].
36 Azrin NH. Improvements in the community-reinforcement approach to alcoholism. Behav Res Ther. 1976;14(5):339-48. [pmid: 971207].
37 O’Farrell TJ, Cutter HSG, Floyd FJ. Evaluating behavioral marital therapy for male alcoholics: Effects on marital adjustment and communication from before to after treatment. Behav Ther. 1985;16:147-67.
38 O’Farrell TJ. A behavioral marital therapy couples’ group program for alcoholics and their spouses. O’Farrell TJ, editor. Treating alcohol problems: Marital and family interventions. New York. Guilford Press. 1993:170-209.
39 Riley AJ, Riley EJ. A controlled study to evaluate directed masturbation in the management of primary orgasmic failure in women. Br J Psychiatry. Nov. 1978;133:404-9. [pmid: 365286].
40 Ersner-Hershfield R, Kopel S. Group treatment of preorgasmic women: evaluation of partner involvement and spacing of sessions. J Consult Clin Psychol. Aug. 1979;47(4):750-9. [pmid: 500911].
41 Everaerd W, Dekker J. A comparison of sex therapy and communication therapy: couples complaining of orgasmic dysfunction. J Sex Marital Ther. Winter. 1981;7(4):278-89. [pmid: 7328681].
42 Zimmer D. Does marital therapy enhance the effectiveness of treatment for sexual dysfunction?. J Sex Marital Ther. Fall. 1987;13(3):193-209. [pmid: 3669080].
43 Hurlbert DF. A comparative study using orgasm consistency training in the treatment of women reporting hypoactive sexual desire. J Sex Marital Ther. Spring. 1993;19(1):41-55. [pmid: 8468709].
44 Jacobson NS, Dobson K, Fruzzetti AE, et al. Marital therapy as a treatment for depression. J Consult Clin Psychol. Aug. 1991;59(4):547-57. [pmid: 1918559].
45 O’Leary KD, Beach SR. Marital therapy: a viable treatment for depression and marital discord. Am J Psychiatry. Feb. 1990;147(2):183-6. [pmid: 2301656].
46 Mehta M. A comparative study of family-based and patient-based behavioural management in obsessive-compulsive disorder. Br J Psychiatry. Jul. 1990;157:133-5. [pmid: 2397347].
47 Emmelkamp PM, de Lange I. Spouse involvement in the treatment of obsessive-compulsive patients. Behav Res Ther. 1983;21(4):341-6. [pmid: 6626105].
48 Emmelkamp PM, de Haan E, Hoogduin CA. Marital adjustment and obsessive-compulsive disorder. Br J Psychiatry. Jan. 1990;156:55-60. [pmid: 1967545].
49 Cobb JP, Mathews AM, Childs-Clarke A, et al. The spouse as co-therapist in the treatment of agoraphobia. Br J Psychiatry. Mar. 1984;144:282-7. [pmid: 6704621].
50 Emmelkamp PM, van Dyck R, Bitter M, et al. Spouse-aided therapy with agoraphobics. Br J Psychiatry. Jan. 1992;160:51-6. [pmid: 1347480].
51 Hand I, Angenendt J, Fischer M, Wilke C. Exposure in-vivo with panic management for agoraphobia: Treatment rationale and long-term outcome. Hand I, Wittchen H-U, editors. Panic and phobias: Empirical evidence of theoretical models and long-term effects of behavioral treatments. Berlin. Springer-Verlag. 1986:104-27.
52 Jannoun L, Munby M, Catalan J, Gelder M. A home-based program for agoraphobia. Behav Ther. 1980;11:294-305.
53 Oatley K, Hodgson D. Influence of husbands on the outcome of their agoraphobic wives’ therapy. Br J Psychiatry. Mar. 1987;150:380-6. [pmid: 3664109].
54 Barlow DH, O’Brien GT, Last CG. Couples treatment of agoraphobia. Behav Ther. 1984;15:41-58.
55 Arnow BA, Taylor CB, Agras WS, Telch MJ. Enhancing agoraphobia treatment outcomes by changing couple communication patterns. Behav Ther. 1985;16:452-67.
56 Chambless DL, Ollendick TH. Empirically supported psychological interventions: controversies and evidence. Annu Rev Psychol. 2001;52:685-716. [pmid: 11148322].
57 Nathan PE, Gorman JM. A Guide to Treaments That Work. New York. Oxford University Press. 1998.
58 Kendall PC. Empirically supported psychological therapies. J Consult Clin Psychol. Feb. 1998;66(1):3-6. [pmid: 9489258].
59 Association AP. Diagnostic and Statistical Manual, Third Edition DSM-III. Third ed. 1994.
60 Association AP. Diagnostic and Statistical Manual, Fourth Edition, DSM-IV-TR. Fourth ed. 2000.
61 Cochrane Handbook for Systematic Reviews of Interventions. Higgins JPT, Green S, editors. Version 5.1.0 (updated March 2011) ed. The Cochrane Collaboration. 2011.
62 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
63 Kelley ML, Fals-Stewart W. Couples-versus individual-based therapy for alcohol and drug abuse: effects on children’s psychosocial functioning. J Consult Clin Psychol. Apr. 2002;70(2):417-27. [pmid: 11952200].
64 O’Farrell TJ, Murphy M, Alter J, et al. Brief family treatment intervention to promote continuing care among alcohol-dependent patients in inpatient detoxification: a randomized pilot study. J Sub Abuse Treat. Apr. 2008;34(3):363-9.
65 O’Farrell TJ, Kleinke CL, Cutter HS. Sexual adjustment of male alcoholics: changes from before to after receiving alcoholism counseling with and without marital therapy. Addict Behav. May–Jun. 1998;23(3):419-25. [pmid: 9668941].
66 Fals-Stewart W, Birchler GR, O’Farrell TJ. Behavioral couples therapy for male substance-abusing patients: effects on relationship adjustment and drug-using behavior. J Consult Clin Psychol. Oct. 1996;64(5):959-72. [pmid: 8916625].
67 Fals-Stewart W, O’Farrell TJ, Birchler GR. Behavioral couples therapy for male methadone maintenance patients: effects on drug-using behavior and relationship adjustment. Behav Ther. 2001;32:391-411.
68 Fals-Stewart W, O’Farrell TJ. Behavioral family counseling and naltrexone for male opioid-dependent patients. J Consult Clin Psychol. Jun. 2003;71(3):432-42. [pmid: 12795568].
69 Fals-Stewart W, Klostermann K, Yates BT, et al. Brief relationship therapy for alcoholism: a randomized clinical trial examining clinical efficacy and cost-effectiveness. Psychol Addict Behav. Dec. 2005;19(4):363-71. [pmid: 16366808].
70 Jones HE, Tuten M, O’Grady KE. Treating the partners of opioid-dependent pregnant patients: feasibility and efficacy. Am J Drug Alcohol Abuse. May. 2011;37(3):170-8. [pmid: 21410418].
71 Lam WK, Fals-Stewart W, Kelley ML. Parent training with behavioral couples therapy for fathers’ alcohol abuse: effects on substance use, parental relationship, parenting, and CPS involvement. Child Maltreat. Aug. 2009;14(3):243-54. [pmid: 19502478].
72 McCrady BS, Epstein EE, Hirsch LS. Issues in the implementation of a randomized clinical trial that includes Alcoholics Anonymous: studying AA-related behaviors during treatment. J Stud Alcohol. Nov. 1996;57(6):604-12. [pmid: 8913991].
73 Walitzer KS, Dermen KH. Alcohol-focused spouse involvement and behavioral couples therapy: evaluation of enhancements to drinking reduction treatment for male problem drinkers. J Consult Clin Psychol. Dec. 2004;72(6):944-55. [pmid: 15612842].
74 Fals-Stewart W, Birchler GR, Kelley ML. Learning sobriety together: A randomized clinical trial examining behavioral couples therapy with alcoholic female patients. J Consult Clin Psychol. Jun. 2006;74(3):579-91. [pmid: 16822114].
75 McCrady BS, Epstein EE, Cook S, et al. A randomized trial of individual and couple behavioral alcohol treatment for women. J Consult Clin Psychol. Apr. 2009;77(2):243-56. [pmid: 19309184].
76 Winters J, Fals-Stewart W, O’Farrell TJ, et al. Behavioral couples therapy for female substance-abusing patients: effects on substance use and relationship adjustment. J Consult Clin Psychol. Apr. 2002;70(2):344-55. [pmid: 11952192].
77 Carroll KM, Ball SA, Nich C, et al. Targeting behavioral therapies to enhance naltrexone treatment of opioid dependence: efficacy of contingency management and significant other involvement. Arch Gen Psychiatry. Aug. 2001;58(8):755-61. [pmid: 11483141].
78 Fals-Stewart W, Lam WK. Brief behavioral couples therapy for drug abuse: A randomized clinical trial examining clinical efficacy and cost-effectiveness. Fam Syst Health. 2008;26(4):377-92.
79 Fals-Stewart W, O’Farrell TJ, Lam WKK. Behavioral couple therapy for gay and lesbian couples with alcohol use disorders. J Subst Abuse Treat. Dec. 2009;37(4):379-87. [pmid: 19553063].
80 Kirby KC, Marlowe DB, Festinger DS, et al. Community reinforcement training for family and significant others of drug abusers: a unilateral intervention to increase treatment entry of drug users. Drug Alcohol Depend. Aug. 2. 1999;56(1):85-96. [pmid: 10462097].
81 Miller WR, Meyers RJ, Tonigan JS. Engaging the unmotivated in treatment for alcohol problems: a comparison of three strategies for intervention through family members. J Consult Clin Psychol. Oct. 1999;67(5):688-97. [pmid: 10535235].
82 O’Farrell TJ, Murphy M, Alter J, et al. Behavioral family counseling for substance abuse: a treatment development pilot study. Addict Behav. Jan. 2010;35(1):1-6. [pmid: 19717243].
83 Meyers RJ, Miller WR, Smith JE, et al. A randomized trial of two methods for engaging treatment-refusing drug users through concerned significant others. J Consult Clin Psychol. Oct. 2002;70(5):1182-5. [pmid: 12362968].
84 Fals-Stewart W, O’Farrell TJ, Feehan M, et al. Behavioral couples therapy versus individual-based treatment for male substance-abusing patients. An evaluation of significant individual change and comparison of improvement rates. J Substance Abuse Treat. Apr. 2000;18(3):249-54.
85 Fals-Stewart W, Kashdan TB, O’Farrell TJ, et al. Behavioral couples therapy for drug-abusing patients: effects on partner violence. J Substance Abuse Treat. Mar. 2002;22(2):87-96.
86 McCrady BS, Epstein EE, Hirsch LS. Maintaining change after conjoint behavioral alcohol treatment for men: outcomes at 6 months. Addiction. Sep. 1999;94(9):1381-96. [pmid: 10615723].
87 McCrady BS, Epstein EE, Kahler CW. Alcoholics anonymous and relapse prevention as maintenance strategies after conjoint behavioral alcohol treatment for men: 18-month outcomes. J Consult Clin Psychol. Oct. 2004;72(5):870-8. [pmid: 15482044].
88 Sobell LCSM. Timeline followback user’s guide A calendar method for assessing alcohol and drug use. Toronto. Addiction Research Foundation. 1996.
89 Miller IW, Solomon DA, Ryan CE, et al. Does adjunctive family therapy enhance recovery from bipolar I mood episodes?. J Affect Disord. Nov. 1. 2004;82(3):431-6. [pmid: 15555694].
90 Miklowitz DJ, Simoneau TL, George EL, et al. Family-focused treatment of bipolar disorder: 1-year effects of a psychoeducational program in conjunction with pharmacotherapy. Biol Psychiatry. Sep. 15. 2000;48(6):582-92. [pmid: 11018229].
91 Rea MM, Tompson MC, Miklowitz DJ, et al. Family-focused treatment versus individual treatment for bipolar disorder: results of a randomized clinical trial. J Consult Clin Psychol. Jun. 2003;71(3):482-92. [pmid: 12795572].
92 Miklowitz DJ, Otto MW, Frank E, et al. Psychosocial treatments for bipolar depression: a 1-year randomized trial from the Systematic Treatment Enhancement Program. Arch Gen Psych. Apr. 2007;64(4):419-26.
93 Perlick DA, Miklowitz DJ, Lopez N, et al. Family-focused treatment for caregivers of patients with bipolar disorder. Bipolar Disord. Sep. 2010;12(6):627-37. [pmid: 20868461].
94 Clarkin JF, Carpenter D, Hull J, et al. Effects of psychoeducational intervention for married patients with bipolar disorder and their spouses. Psych Services. Apr. 1998;49(4):531-3.
95 Miklowitz DJ, Otto MW, Frank E, et al. Intensive psychosocial intervention enhances functioning in patients with bipolar depression: results from a 9-month randomized controlled trial. Am Journal Psych. Sep. 2007;164(9):1340-7.
96 Miklowitz DJ, Thomson MC. Family variables and interventions in schizophrenia. Sholevar GP, Schwoeri LD, editors. Textbook of marital and family therapy. Washington DC. American Psychiatric Publishing, Inc. 2003.
97 Solomon DA, Keitner GI, Ryan CE, et al. Preventing recurrence of bipolar I mood episodes and hospitalizations: family psychotherapy plus pharmacotherapy versus pharmacotherapy alone. Bipolar Disord. Nov. 2008;10(7):798-805. [pmid: 19032711].
98 Miller IW, Keitner GI, Ryan CE, et al. Family treatment for bipolar disorder: family impairment by treatment interactions. J Clin Psych. May. 2008;69(5):732-40.
99 Mueser KT, Glynn SM, Cather C, et al. Family intervention for co-occurring substance use and severe psychiatric disorders: participant characteristics and correlates of initial engagement and more extended exposure in a randomized controlled trial. Addict Behav. Oct. 2009;34(10):867-77. [pmid: 19375870].
100 Mueser KT, Glynn SM, Cather C, et al. A randomized controlled trial of family intervention for co-occurring substance use and severe psychiatric disorders. Schizophr Bull. 2012. In Press.
101 Dyck DG, Short RA, Hendryx MS, et al. Management of negative symptoms among patients with schizophrenia attending multiple-family groups. Psychiatr Serv. Apr. 2000;51(4):513-9. [pmid: 10737828].
102 Dyck DG, Hendryx MS, Short RA, et al. Service use among patients with schizophrenia in psychoeducational multiple-family group treatment. Psychiatr Serv. Jun. 2002;53(6):749-54. [pmid: 12045314].
103 McDonell MG, Short RA, Hazel NA, et al. Multiple-family group treatment of outpatients with schizophrenia: impact on service utilization. Fam Process. Sep. 2006;45(3):359-73. [pmid: 16984076].
104 Mueser KT, Sengupta A, Schooler NR, et al. Family treatment and medication dosage reduction in schizophrenia: effects on patient social functioning, family attitudes, and burden. J Consult Clin Psychol. Feb. 2001;69(1):3-12. [pmid: 11302274].
105 Weine S, Kulauzovic Y, Klebic A, et al. Evaluating a multiple-family group access intervention for refugees with PTSD. J Marital Fam Ther. Apr. 2008;34(2):149-64. [pmid: 18412823].
106 Aubin S, Heiman JR, Berger RE, et al. Comparing Sildenafil alone vs. Sildenafil plus brief couple sex therapy on erectile dysfunction and couples’ sexual and marital quality of life: a pilot study. J Sex Marital Ther. 2009;35(2):122-43. [pmid: 19266381].
107 Banner LL, Anderson RU. Integrated sildenafil and cognitive-behavior sex therapy for psychogenic erectile dysfunction: a pilot study. J Sex Med. Jul. 2007;4(4 Pt 2):1117-25. [pmid: 17627724].
108 Rosen RC, Riley A, Wagner G, et al. The international index of erectile function (IIEF): a multidimensional scale for assessment of erectile dysfunction. Urology. Jun. 1997;49(6):822-30. [pmid: 9187685].
109 Spanier GB. Effects of behavioral marital therapy: a meta-analysis of randomized controlled trials. J Consult Clin Psychol. 1976;38:15-28.
110 Schaefer MT, Olson DH. Assessing intimacy: the pair inventory. J Marital Fam Ther. 1980;7:47-60.
111 Althof SE, Corty EW, Levine SB, et al. EDITS: development of questionnaires for evaluating satisfaction with treatments for erectile dysfunction. Urology. Apr. 1999;53(4):793-9. [pmid: 10197859].
112 Beck AT, Ward CH, Mendelson M, et al. An inventory for measuring depression. Arch Gen Psych. Jun. 1961;4:561-71.
113 Beck AT, Epstein N, Brown G, et al. An inventory for measuring clinical anxiety: psychometric properties. J Consult Clin Psychol. Dec. 1988;56(6):893-7. [pmid: 3204199].
114 Cohen S, O’Leary KD, Foran H. A randomized clinical trial of a brief, problem-focused couple therapy for depression. Behav Ther. Dec. 2010;41(4):433-46. [pmid: 21035609].
115 Gorin AA, Le Grange D, Stone AA. Effectiveness of spouse involvement in cognitive behavioral therapy for binge eating disorder. Intern J Eat Disord. May. 2003;33(4):421-33.
116 Fairburn CG, Beglin SJ. The evaluation of a new instrument for detecting eating disorders in community samples. Oxford University. 1991.
117 Fairburn CG, Beglin SJ. Assessment of eating disorders: interview or self-report questionnaire?. Intern J Eat Disord. Dec. 1994;16(4):363-70.
118 McBride CM, Baucom DH, Peterson BL, et al. Prenatal and postpartum smoking abstinence a partner-assisted approach. Am J of Prevent Med. Oct. 2004;27(3):232-8.
119 Miller IW, Bishop S, Norman WH, et al. The Modified Hamilton Rating Scale for Depression: reliability and validity. Psychiatry Res. Feb. 1985;14(2):131-42. [pmid: 3857653].
120 Beck AT, Steer RA, Brown GK. Beck Depression Inventory - Manual. 2nd ed. San Antonio, TX. The Psychological Corporation. 1996.
121 Christensen A, Atkins DC, Berns S, et al. Traditional versus integrative behavioral couple therapy for significantly and chronically distressed married couples. J Consult Clin Psychol. Apr. 2004;72(2):176-91. [pmid: 15065953].
122 Fals-Stewart Felony Complaint. http://www.ag.ny.gov/media_center/2010/feb/feb16a_10.html OR http://www.wivb.com/dpp/search/Fals-Stewart-felony-complaint. Accessed on January 2012.
123 Powers MB, Vedel E, Emmelkamp PM. Behavioral couples therapy (BCT) for alcohol and drug use disorders: a meta-analysis. Clin Psychol Rev. Jul. 2008;28(6):952-62. [pmid: 18374464].
124 Justo LP, Soares BG, Calil HM. Family interventions for bipolar disorder. Cochrane Database Syst Rev. 2007;4:CD005167. [pmid: 17943843].
125 Herz MI, Lamberti JS, Mintz J, et al. A program for relapse prevention in schizophrenia: a controlled study. Arch Gen Psych. Mar. 2000;57(3):277-83.
126 Pharoah F, Mari J, Rathbone J, et al. Family intervention for schizophrenia. Cochrane Database Syst Rev. 2010;12:CD000088. [pmid: 21154340].
127 Lehman AF, Steinwachs DM. Translating research into practice: the Schizophrenia Patient Outcomes Research Team (PORT) treatment recommendations. Schizophr Bull. 1998;24(1):1-10. [pmid: 9502542].
128 Lehman AF, Kreyenbuhl J, Buchanan RW, et al. The Schizophrenia Patient Outcomes Research Team (PORT): updated treatment recommendations 2003. Schizophr Bull. 2004;30(2):193-217. [pmid: 15279040].
129 Dixon LB, Dickerson F, Bellack AS, et al. The 2009 schizophrenia PORT psychosocial treatment recommendations and summary statements. Schizophr Bull. Jan. 2010;36(1):48-70. [pmid: 19955389].
130 Glynn SM, Cohen AN, Niv N. New challenges in family interventions for schizophrenia. Expert Rev Neurother. Jan. 2007;7(1):33-43. [pmid: 17187495].
131 Pilling S, Bebbington P, Kuipers E, et al. Psychological treatments in schizophrenia: I. Meta-analysis of family intervention and cognitive behaviour therapy. Psychol Med. Jul. 2002;32(5):763-82. [pmid: 12171372].
132 Pitschel-Walz G, Leucht S, Bauml J, et al. The effect of family interventions on relapse and rehospitalization in schizophrenia--a meta-analysis. Schizophr Bull. 2001;27(1):73-92. [pmid: 11215551].
133 Hornung WP, Feldmann R, Klingberg S, et al. Long-term effects of a psychoeducational psychotherapeutic intervention for schizophrenic outpatients and their key-persons--results of a five-year follow-up. Eur Arch Psychiatry Clin Neurosci. 1999;249(3):162-7. [pmid: 10433131].
134 Tarrier N, Barrowclough C, Porceddu K, et al. The Salford Family Intervention Project: relapse rates of schizophrenia at five and eight years. Br J Psychiatry. Dec. 1994;165(6):829-32. [pmid: 7881788].
135 Barbato A, D’Avanzo B. Marital therapy for depression. Cochrane Database Syst Rev. 2006;2:CD004188. [pmid: 16625597].
136 Henken HT, Huibers MJ, Churchill R, et al. Family therapy for depression. Cochrane Database Syst Rev. 2007;3:CD006728. [pmid: 17636850].
137 Foley SH, Rounsaville BJ, Weissman MM, et al. Individual versus conjoint interpersonal therapy for depressed patients with marital disputes. Int J Family Psychiatry. 1989;10:29-42.
138 Rosenberg M. Society and the adolescent self-image. Princeton, NJ. Princeton University Press. 1965.
139 Monson CM, Fredman SJ, Adair KC, et al. Cognitive-behavioral conjoint therapy for PTSD: pilot results from a community sample. J Trauma Stress. Feb. 2011;24(1):97-101. [pmid: 21351166].
140 Glynn SM, Dixon LB, Cohen A, et al. The Family Member Provider Outreach program. Psychiatric Services. Aug. 2008;59(8):934. [pmid: 18678695].
141 Sayers SL. Coaching into care: a pilot program to enhance outreach to military Veterans and their family members. VA Mental Health Annual Conference. 2011 August 23. Baltimore, Maryland.
142 Sherman MD, Fischer EP, Sorocco K, McFarlane WR. Adapting the Multifamily Group Model to the Veterans Affairs system: The REACH Program. Research and Practice. 2009;40:593-600.