# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Sonja Batten, PhD, Office of Mental Health Services. The key questions and scope were refined with input from a technical expert panel.

## SEARCH STRATEGY

We searched MEDLINE (Ovid) and PsycINFO for randomized controlled trials (RCTs) and systematic reviews published from 1980 to November, 2011 using standard search terms. We limited the search to articles involving adolescents and adults and published in the English language. Search terms included: family, couples, home nursing, legal guardians, couple therapy, family therapy, and marital therapy. The search strategies are presented in Appendix A.

We obtained additional articles from systematic reviews, reference lists of pertinent studies, and suggestions from members of our technical expert panel.

## STUDY SELECTION

Titles and abstracts were reviewed by researchers trained in the critical analysis of literature. Full text versions of potentially eligible articles were retrieved for review. Although our search identified studies of patients with both mental health and physical health conditions published from 1980 to the present, due to the volume of eligible articles identified by our search, we narrowed our inclusion criteria at the time of full-text review to include the following:

- RCT conducted in the United States or systematic review or meta-analysis of RCTs.
- Study involves a patient age 18 and over with a DSM-III or DSM-IV mental health condition.59, 60
- Intervention must involve family members or caregivers of the adult patient (patient may or may not be present for the intervention).
- Study reports intermediate patient outcomes or final outcomes of interest as outlined in the analytic framework (Figure 1).
- Control group must be used; control group may be no treatment/placebo or an alternative active treatment (e.g., usual care, individually-oriented treatment, or another family/couple-oriented intervention).
- Study published in a peer-reviewed publication after 1995.

## DATA ABSTRACTION

We abstracted the following study characteristics for each included study: author, date of publication, funding source, sample characteristics (gender, age, race/ethnicity, marital status, education, Veteran status, family characteristics, and recruitment method), inclusion and exclusion criteria (mental health condition, how the condition was assessed, family/caregivers involved, specific inclusion and exclusion criteria), treatment groups, intervention characteristics (format, whether manualized, number of sessions, treatment length, approach, and treatment integrity), outcomes assessed (list of patient, family/couple, and intermediate outcomes assessed), and study quality (allocation concealment, blinding, analysis approach, description of withdrawals). We extracted final outcomes (patient outcomes and family/couple functioning measures) and intermediate outcomes, by mental health condition, for each treatment arm, where reported, and noted whether the analysis included all patients randomized or study completers only. Final patient outcomes of interest were: symptom improvement, global functioning, quality of life, length of stay, disposition at discharge, and health care utilization. The family/couple functioning outcome of interest in all studies was global function or satisfaction. We also were interested in intimate partner violence, communication skills and relationship conflict, observational data of communication skills among couples, and sexual satisfaction. Sexual satisfaction was abstracted under patient symptom improvement for studies of treatment for sexual dysfunction and as a measure of couples functioning in the studies of treatment for substance abuse. Intermediate outcomes of interest were treatment attendance, adherence, social support for the patient, and satisfaction with care. We assessed outcomes at a number of different time points in order to determine initial and persistent changes in behavior. When available, we examined behavior at baseline, after treatment (post-treatment), short-term follow-up (up to 6 months), and long-term follow-up (up to 12 months or longer) across treatment arms. All abstraction was done by trained research personnel and verified by a second research associate under the supervision of the Principal Investigator.

## QUALITY ASSESSMENT

We assessed study quality of included trials (all were randomized, controlled trials) according to the following criteria: 1) adequate allocation concealment, 2) blinding of key study personnel, 3) analysis by intention-to-treat, and 4) reporting of number of withdrawals/dropouts by group assignment.61 We also considered whether the treatment protocol was manualized and whether the quality and consistency of the treatment protocol was evaluated (i.e., treatment integrity) as part of the quality assessment for individual studies. Studies were rated as good, fair, or poor quality. A rating of good generally indicated that the treatment was manualized and integrity was assessed. In addition, the trial reported adequate allocation concealment, blinding, analysis by intent-to-treat, and reasons for dropouts/attrition. Studies were generally rated poor if the treatment was neither manualized nor assessed for quality, the method of allocation concealment was inadequate or not defined, blinding was not defined, analysis by intent-to-treat was not utilized, and reasons for dropouts/attrition were not reported and/or there was a high rate of attrition.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by clinical condition. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question and drew conclusions based on qualitative synthesis of the findings or pooled analyses where feasible.

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence using the method reported by Owens et al.62 The overall evidence was rated as: (1) high, meaning high confidence that the evidence reflects the true effect; (2) moderate, indicating moderate confidence that further research may change our confidence in the estimate of effect and may change the estimate; (3) low, meaning there is low confidence that the evidence reflects the true effect; or (4) insufficient, indicating that evidence either is unavailable or does not permit a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by members of our technical expert panel and VA clinical leadership. Their comments and our responses are presented in Appendix C. Responses were also incorporated into the final report.