# INTRODUCTION

Since 2008, the President has signed two new laws establishing or expanding VA authority to provide family services for Veterans’ mental health care. The first law, Public Law 110-387: Veterans’ Mental Health and Other Care Improvements Act of 2008, was signed into law on October 10, 2008. Section 301 of the Act amends title 38 of United States Code (U.S.C.) § 1701(5)(B) and 38 U.S.C. § 1782(a) and (b). This law expands VA authority to provide enhanced family mental health services, such as consultation, professional counseling, marriage and family counseling, and training to families of patients with Service Connected and Non-Service Connected injuries or conditions when 1) no Veteran treatment would otherwise occur without the family member’s involvement, 2) the Veteran’s treatment would be less or not effective without family member’s involvement, 3) or, the treatment can be delivered most efficiently when the family member is included in treatment. The second law, Public Law 111-163: Caregivers and Veterans Omnibus Health Services Act, signed in May, 2010, allows, among other things, the VA authority to provide these same services to family caregivers of Veterans and directs the VA to provide additional benefits (e.g., financial stipends and health care benefits) to a select group of eligible caregivers, namely those providing essential care to Veterans injured in Operation Iraqi Freedom (OIF) and Operation Enduring Freedom (OEF). Of note, current eligibility criteria for VA family-related services do not extend to close friends or intimate partners who do not reside with the Veteran. These new laws, along with the VA’s adoption in primary care of Patient-Aligned Care Teams, or a patient-centered medical home model, recognize the important role families have on a treatment team and their influence over a patient’s care and related outcomes. Synthesis of the scientific literature on the effectiveness of involving family or intimate partners (referred to hereafter as family, encompassing both intimate partners, spouses, and other family members) in psychosocial interventions to treat or improve a broad range of mental health conditions, family problems, marital strain, and physical health conditions, including an examination of both patient outcomes and caregiver and family outcomes, is essential to shaping the VA’s provision of family involved care but beyond the scope of a single review. The focus of the present review is on one of these vital areas for synthesis: the effectiveness of family involved interventions in treating mental health conditions. This synthesis is intended to help clarify the evidence for potential best practices within the VA in family involved mental health care to guide both policy and clinical practice. While these family or couple interventions likely also affect caregivers, the focus of this review is specifically on patient outcomes (versus caregiver or family member’s personal functioning), including patients’ family functioning.

## TYPES OF FAMILY TREATMENTS FOR MENTAL HEALTH CONDITIONS

While individual psychotherapies for mental health problems have long been the standard for mental health care, family problems are pronounced among patients with mental health conditions. Among OEF/OIF Veterans recently returning from deployment, interpersonal problems have been identified as increasing at a greater rate than any other health-related problem,1 and relationship distress in intimate relationships can facilitate or hinder treatment seeking.2 Consequently, family involvement has been explored for a number of conditions, including depression,3 substance use,4 bipolar disorder,5 schizophrenia,6 panic disorder with agoraphobia,7 and posttraumatic stress disorder (PTSD).8 Family interventions for mental health conditions can take multiple forms, as outlined by Baucom and colleagues,9 and may fall across any given category or combination of categories.

### Partner or Family Assisted Treatment9

In this case, family member(s) act as surrogate therapists or coaches to help the patient. Typically, the family aids the patient in completing out-of-session homework within a cognitive-behavioral treatment, and relationships between the patient and family are not a focus of treatment. This category of family involvement capitalizes on prior work establishing robust associations between social support, instrumental support, and treatment adherence across multiple medical conditions.10

### Disorder Specific Couple or Family Treatment9

For interventions taking this approach, family behavior and relationships that are theorized to fuel disorder symptoms are addressed. Family relationships are targeted only to the extent to which they directly influence the patient’s disorder or treatment. Such interventions, especially for schizophrenia or bipolar disorder, often target expressed emotions (EE) or related constructs. EE includes family members’ expressed criticism, hostility, and emotional over-involvement toward the patient and is tied to poor medication adherence, including among patients with schizophrenia,11 and greater relapse rates and symptom severity among patients with schizophrenia, eating disorders, depression, PTSD, and bipolar disorder,12–15 EE likely reflects disturbances within the entire family system, including family organization, emotional climate, and transactions.16 Supported mechanisms underlying EE include a family member’s attributions of patient’s negative behavior to controllable factors, personal factors, and beliefs that the patient is not making appropriate efforts at self-improvement. 16, 17

Additionally, behavior patterns between family and patients and specific to a given disorder can be conceptualized as maintaining the condition, with reciprocal associations postulated between mental health symptoms and family functioning.18, 19 For example, environmental contingencies have been theorized to maintain use for substance use disorders20 and avoidance of trauma cues for individuals with PTSD.21 Additionally, for those with substance use disorders, relationship distress may increase substance use cravings, reinforce the use of substances to cope with distress,19 or even motivate patients to remain sober due to fears of relationship dissolution.22

### General Marital OR Family Treatment9

Interventions taking this approach directly address general family or relationship distress, under the assumption that improving family functioning will reduce patient stressors and improve patient functioning.9

## PRESENT STUDY

With one known exception,9 prior reviews have focused on a discrete number of mental health conditions at a time (i.e., a review of family treatments for depression). To the best of our knowledge, the most recent comprehensive review that included family involved interventions for any mental health condition was published in 1998.^9^ A comprehensive review is called for to update the evidence, to serve VA needs, and to facilitate comparisons of the evidence across conditions. Additionally, such a review can highlight family interventions for mental health conditions that may not have been addressed in recent prior reviews due to too few RCTs to warrant a disorder specific review (i.e., sexual functioning disorders, PTSD). Prior reviews are potentially less relevant to VA populations due to their focus on studies conducted both nationally and internationally. Studies conducted outside the US (i.e., family interventions within Eastern societies) may be less relevant to US Veterans, given important cultural differences in family structure and function. Finally, given the VA’s interest in including families in order to improve the quality of care provided in the VA, an important question to address is the comparative efficacy of family involved interventions versus individual-only treatment approaches.

In the only known comprehensive review of family involved psychosocial treatments for mental health conditions, Baucom and colleagues9 established categories for evaluating the efficacy of a couple/family intervention, based upon Chambless and Hollon’s23 definition of empirically supported treatments (i.e., “clearly specified psychological treatments shown to be efficacious in controlled research with a delineated population,” p. 7). They define an efficacious treatment as one in which the intervention has demonstrated superiority over waitlist control in studies conducted by two independent research teams. An efficacious and specific intervention has demonstrated superiority in at least two studies conducted by independent research teams over a placebo, nonspecific, or alternative intervention. They modify these labels with possibly (i.e., possibly efficacious and possibly efficacious and specific) when the above criteria are met by a single study. Using these criteria, the conclusions from the 1998 review are outlined in Table 1.

Table 1 Empirically Supported Couple and Family Treatments for Mental Health Conditions (Baucom 1998^9^)

Mental Health Condition | Intervention | Efficacy Status
Schizophrenia | Behavioral Family Therapy24–28 | 1
Schizophrenia | Supportive Family Therapy29 30–32 | 1
Schizophrenia | Family systems33 | 3
Alcohol Use Disorders | Community Reinforcement Approach34–36 | 3
Alcohol Use Disorders | Behavioral Marital Therapy37, 38 | 3
Female orgasmic disorder | Sexual skill training for primary female orgasmic disorder39, 40 | 3
Female orgasmic disorder | Masters and Johnson for female orgasmic disorders41 | 3
Mixed female sexual dysfunctions | Behavioral Marital Therapy + Masters and Johnson42 | 3
Female hypoactive sexual desire | Marital + orgasm consistency training43 | 3
Depression | Behavioral Marital Therapy44, 45 | 4
Obsessive Compulsive Disorder | Family-assisted exposure therapy46 | 4
Obsessive Compulsive Disorder | Partner-assisted exposure therapy47, 48 | 4
Agoraphobia | Partner-assisted exposure therapy49–53 | 4
Agoraphobia | Partner-assisted Cognitive-Behavioral Therapy54 | 4
Agoraphobia | Partner-assisted exposure + couple communication training55 | 4

Efficacy Status:

1 = Efficacious & Specific; superior to placebo, nonspecific, or alternative intervention in at least two studies conducted by independent research teams.

2 = Efficacious; superior to waitlist in RCTs conducted by two independent research teams.

3 = Possibly Efficacious & Specific; criteria met for efficacious and specific from a single study.

4 = Possibly Efficacious; criteria met for efficacious from a single study.9, 23

Baucom and colleagues9 concluded that family involved treatments for schizophrenia were clearly efficacious for reducing relapse rates. These family treatments often incorporated elements from all three types of approaches to family involvement (family assisted interventions, disorder specific interventions, and family/couple therapy). These findings are largely consistent with larger reviews of empirically supported treatments.23 Chambless and Ollendick56 reviewed the American Psychiatric Association’s Task Force and various other work groups’ recommendations for psychosocial interventions considered efficacious and possibly efficacious, using similar criteria and including family treatments. Their review largely overlaps with Baucom and colleagues’9 conclusions, with a few exceptions. First, one group57 identified behavioral marital therapy as efficacious for depression among patients with marital discord and a second58 identified behavioral marital therapy as possibly efficacious for depression. Second, multiple work groups identified the Community Reinforcement Approach and behavioral couple therapy for alcohol use disorders as either efficacious or possibly efficacious.

## OBJECTIVES

The present study provides an update to prior work conducted by Baucom9 and others56 by examining the effectiveness of family involved psychosocial treatments in US samples for mental health conditions. Due to our focus solely on mental health conditions and US studies, our findings are not intended to be a strict replication and extension of Baucom and colleagues’9 prior review. We conducted a systematic review of randomized controlled trials (RCTs) of psychosocial interventions, addressing a mental health condition through a family intervention. Given prior work already conducted in this area, we focused on only those studies conducted after 1995. To optimize relevance to Veterans and the VA, in addition to a focus on US studies, we limited our review to improvements in patient functioning, including patient symptoms and family/couple functioning (primary outcomes) and treatment adherence, treatment attendance, patient satisfaction, and social support for patients (intermediate outcomes). Figure 1 provides our analytic framework, depicting our population, interventions, comparators, and outcomes of interest. We were interested in reviewing the evidence of the efficacy of family involved interventions (compared to no psychosocial intervention), as well as the degree to which family involved interventions are superior to an alternative individually-focused or family involved intervention (i.e., specificity).

Figure 1 Analytic Framework

We sought to address two specific questions:

Key Question #1 What is the efficacy of family involved interventions in improving outcomes for adult patients with mental health conditions [i.e., how do family involved psychosocial treatments compare to no psychosocial treatment: (a) waitlist/no treatment or (b) medication management only]?
Key Question #2 What is the effectiveness of family involved interventions compared to alternative interventions in improving outcomes for adult patients with mental health conditions [i.e., how do family involved interventions compare to (a) any individually-oriented psychosocial intervention or (b) any alternative family involved intervention]?