# FOREST PLOTS FROM POOLED ANALYSES FOR ALCOHOL AND DRUG USE STUDIES

Figure 1a Percent Days Abstinent, Differences between BCT and ICBT: Studies Not Conducted with Data from Fals-Stewart

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 1b Percent Days Abstinent, Differences between BCT and ICBT: Studies Conducted with Data from Fals-Stewart

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy; EtOH = alcohol

Figure 2 Percent Days Abstinent, Differences between BCT and ICBT: Alcohol Use Disorder Studies Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy; EtOH = alcohol

Figure 3 Percent Days Heavy Drinking, Differences between BCT and ICBT: Alcohol Use Disorder Studies Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences.

Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 4 Percent Days Abstinent, Differences between BCT and ICBT: Drug Use Disorder Studies Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 5 Relationship Adjustment using Dyadic Adjustment Scale, Difference in Mean Scores between BCT and ICBT: Alcohol Use Disorder Studies Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy; EtOH = alcohol

Figure 6 Relationship Adjustment using Dyadic Adjustment Scale, Difference in Mean Scores between BCT and ICBT: Drug Use Disorder Studies Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 7 Percent Days Abstinent, Differences between BCT and ICBT: Studies with Female Subjects Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 8 Relationship Adjustment using Dyadic Adjustment Scale, Difference in Mean Scores between BCT and ICBT: Studies with Female Subjects Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy

Figure 9 Percent Days Abstinent, Differences between BCT and ICBT: Studies with Male Subjects Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy; EtOH = alcohol

Figure 10 Relationship Adjustment using Dyadic Adjustment Scale, Difference in Mean Scores between BCT and ICBT: Studies with Male Subjects Only

* Horizontal bars for each study represent the study’s confidence interval. Confidence intervals extending below 0 indicate non-significant differences. Size of box or diamond reflects sample size.

BCT = Behavioral Couple or Marital Therapy; ICBT = Individual Cognitive-Behavioral Therapy; EtOH = alcohol