# EVIDENCE TABLES

Table 1 Study Descriptive Information – Substance Abuse Studies

Table 2 Patient Outcomes – Substance Abuse Studies

Table 3 Family Outcomes – Substance Abuse Studies

Table 4 Intermediate Outcomes – Substance Abuse Studies

Table 5 Study Descriptive Information - Bipolar Disorder Studies

Table 6 Patient Outcomes - Bipolar Disorder Studies

Table 7 Family Outcomes - Bipolar Disorder Studies

Table 8 Intermediate Outcomes - Bipolar Disorder Studies

Table 9 Study Descriptive Information - Schizophrenia Spectrum Disorder Studies

Table 10 Patient Outcomes - Schizophrenia Spectrum Disorder Studies

Table 11 Family Outcomes - Schizophrenia Spectrum Disorder Studies

Table 12 Intermediate Outcomes - Schizophrenia Spectrum Disorder Studies

Table 13 Study Descriptive Information - Post Traumatic Stress Disorder (PTSD) Studies

Table 14 Patient Outcomes - Post Traumatic Stress Disorder Studies

Table 15 Family Outcomes - Post Traumatic Stress Disorder Studies

Table 16 Intermediate Outcomes - Post Traumatic Stress Disorder Studies

Table 17 Study Descriptive Information - Sexual Functioning Disorders Studies

Table 18 Patient Outcomes - Sexual Functioning Disorders Studies

Table 19 Family Outcomes - Sexual Functioning Disorders Studies

Table 20 Intermediate Outcomes - Sexual Functioning Disorders Studies

Table 21 Study Descriptive Information - Depression, Eating Disorders, and Smoking Cessation Studies

Table 22 Patient Outcomes - Depression, Eating Disorders, and Smoking Cessation Studies

Table 23 Family Outcomes - Depression, Eating Disorders, and Smoking Cessation Studies

Table 24 Intermediate Outcomes - Depression, Eating Disorders, and Smoking Cessation