# CRITERIA USED IN QUALITY ASSESSMENT62

Risk of bias | Internal validity: study design and the quality of individual studies included in the review. Study design limitations may bias the estimates of treatment effect (such as lack of allocation concealment, or lack of blinding). Other areas for potential bias include stopping early for benefit and selective outcome reporting.
Consistency | The effect sizes from the included studies are similar and have the same direction of effect (positive or negative).
Directness | Interventions are directly related to health outcomes. For CERs, head-to-head comparisons are made. Indirectness is suspected if surrogate or intermediate outcomes are used instead of health outcomes. For CERs, indirectness is also suspected if more than one body of evidence is needed to link interventions, ad in the das with placebo controlled trials. Directness also includes applicability and relevance of the included studies to the VA population or to specific subpopulations within the VA. Applicability may also include settings (e.g., primary care vs. specialty care) and physician experience.
Precision | The degree of certainty surrounding an estimate of effect for each outcome of interest. Uncertainty of effect does not allow for a clinically useful conclusion, and is unable to rule out an important benefit or harm.
Risk of publication bias | Publication bias can result in an overestimate of effect. Publication bias is suspected if evidence is derived from a small number of commercially funded trials with small sample sizes and a small number of event.