# References

1 Defense and Veterans Brain Injury Center. Service Members and Veterans. http://dvbic.dcoe.mil/audience/service-members-veterans. Accessed April 13, 2018.
2 Brundage JF, Taubman SB, Hunt DJ, Clark LL. Whither the “signature wounds of the war” after the war: estimates of incidence rates and proportions of TBI and PTSD diagnoses attributable to background risk, enhanced ascertainment, and active war zone service, active component, U.S. Armed Forces, 2003–2014. MSMR. 2015;22(2):2–11.
3 Defense and Veterans Brain Injury Center. DoD Worldwide Numbers for TBI. http://dvbic.dcoe.mil/dod-worldwide-numbers-tbi. Accessed April 13, 2018.
4 Hoffman SW, DePalma RG, Cifu DX. Veteran affairs traumatic brain injuy conference: state of the art. Brain Inj. 2017;31(8):1165–1167.28981344
5 Taylor BC, Hagel Campbell E, Nugent S, . Three year trends in Veterans Health Administration uilization and costs after traumatic brain injury screening among Veterans with mild traumatic brain injury. J Neurotrauma. 2017;34(17):2567–2574.28482747
6 Munn ZM, S.; Lisy, K.; Riitano, D.; Tufanaru, C. Methodological guidance for systematic reviews of observational epidemiological studies reporting prevalence and incidence data. Int J Evid Based Healthc. 2015;13(3):147–153.26317388
7 Tufanaru C, Munn Z, Aromataris E, Campbell J, Hopp L. Chapter 3. Systematic reviews of effectiveness. In: Aromataris E, Munn Z, eds. Joanna Briggs Institute Reviewer’s Manual. The Joanna Briggs Institute; 2017.
8 Cohen J. Statistical Power Analysis for the Behavioral Sciences (2nd ed.). Hillsdale, NJ: Lawrence Earlbaum Associates; 1988.
9 Owens DK, Lohr KN, Atkins D, . AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63:513–523.19595577
10 Adams RS, Corrigan JD, Mohr BA, Williams TV, Larson MJ. Traumatic brain injury and post-deployment binge drinking among male and female army active duty service members returning from Operation Enduring Freedom/Operation Iraqi Freedom. J Neurotrauma. 2017;34(7):1457–1465.27762655
11 Cifu DX, Taylor BC, Carne WF, . Traumatic brain injury, posttraumatic stress disorder, and pain diagnoses in OIF/OEF/OND Veterans. J Rehabil Res Dev. 2013;50(9):1169–1176.24458958
12 Fonda JR, Fredman L, Brogly SB, McGlinchey RE, Milberg WP, Gradus JL. Traumatic Brain Injury and Attempted Suicide Among Veterans of the Wars in Iraq and Afghanistan. Am J Epidemiol. 2017;186(2):220–226.28472407
13 Grossbard J, Malte CA, Lapham G, . Prevalence of alcohol misuse and follow-up care in a national sample of OEF/OIF VA patients with and without TBI. Psychiatr Serv. 2017;68(1):48–55.27476804
14 Jaramillo CA, Cooper DB, Wang CP, . Subgroups of US IRAQ and Afghanistan veterans: associations with traumatic brain injury and mental health conditions. Brain Imaging Behav. 2015;9(3):445–455.25963862
15 Johnson LA, Eick-Cost A, Jeffries V, Russell K, Otto JL. Risk of alcohol use disorder or other drug use disorder among U.S. Service members following traumatic brain injury, 2008–2011. Mil Med. 2015;180(2):208–215.25643389
16 Kontos AP, Kotwal RS, Elbin RJ, . Residual effects of combat-related mild traumatic brain injury. J Neurotrauma. 2013;30(8):680–686.23031200
17 Macera CA, Aralis HJ, Macgregor AJ, Rauh MJ, Galarneau MR. Postdeployment symptom changes and traumatic brain injury and/or posttraumatic stress disorder in men. J Rehabil Res Dev. 2012;49(8):1197–1208.23341312
18 Pogoda TK, Stolzmann KL, Iverson KM, . Associations between traumatic brain injury, suspected psychiatric conditions, and unemployment in Operation Enduring Freedom/Operation Iraqi Freedom veterans. J Head Trauma Rehabil. 2016;31(3):191–203.25310289
19 Seal KH, Bertenthal D, Samuelson KW, Maguen S, Kumar S, Vasterling JJ. Association between mild traumatic brain injury and mental health problems and self-reported cognitive dysfunction in Iraq and Afghanistan veterans. J Rehabil Res Dev. 2016;53(2):185–198.27148692
20 Taylor BC, Hagel Campbell E, Nugent, S, . Fiscal Year 2014 VA Utilization Report for Iraq and Afghanistan War Veterans Diagnosed with TBI. VA Polytrauma and Blast-Related Injuries QUERI #PLY 05-2010-2. http://www.polytrauma.va.gov/TBIReports/FY14-TBI-Diagnosis-HCU-Report.pdf. Published November 2015. Accessed September 20, 2017.
21 Baldassarre M, Smith B, Harp J, . Exploring the Relationship Between Mild Traumatic Brain Injury Exposure and the Presence and Severity of Postconcussive Symptoms Among Veterans Deployed to Iraq and Afghanistan. PM R. 2015;7(8):845–858.25758529
22 Brenner LA, Ivins BJ, Schwab K, . Traumatic brain injury, posttraumatic stress disorder, and postconcussive symptom reporting among troops returning from iraq. J Head Trauma Rehabil. 2010;25(5):307–312.20042982
23 Bryan CJ, Clemans TA. Repetitive traumatic brain injury, psychological symptoms, and suicide risk in a clinical sample of deployed military personnel. JAMA Psychiatry. 2013;70(7):686–691.23676987
24 Bryan CJ, Clemans TA, Hernandez AM, Rudd MD. Loss of consciousness, depression, posttraumatic stress disorder, and suicide risk among deployed military personnel with mild traumatic brain injury. J Head Trauma Rehabil. 2013;28(1):13–20.23076097
25 Bryant RA, Baker MT, Mintz J, . The role of posttraumatic stress in acute postconcussive symptoms following blast injury in combat. Psychother Psychosom. 2015;84(2):120–121.25720392
26 Carlson KF, Nelson D, Orazem RJ, Nugent S, Cifu DX, Sayer NA. Psychiatric diagnoses among Iraq and Afghanistan war veterans screened for deployment-related traumatic brain injury. J Trauma Stress. 2010;23(1):17–24.20127725
27 Gaines KD, Soper HV, Berenji GR. Executive Functioning of Combat Mild Traumatic Brain Injury. Appl Neuropsychol Adult. 2016;23(2):115–124.26496530
28 Heltemes KJ, Dougherty AL, MacGregor AJ, Galarneau MR. Alcohol abuse disorders among U.S. service members with mild traumatic brain injury. Mil Med. 2011;176(2):147–150.21366075
29 Hoge CW, McGurk D, Thomas JL, Cox AL, Engel CC, Castro CA. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. 2008;358(5):453–463.18234750
30 King PR, Donnelly KT, Warner GC, Wade M, Pigeon WR. The natural history of sleep disturbance among OEF/OIF veterans with TBI and PTSD and the role of proxy variables in its measurement. J Psychosom Res. 2017;96:60–66.28545794
31 Mac Donald CL, Johnson AM, Wierzechowski L, . Outcome trends after us military concussive traumatic brain injury. J Neurotrauma. 2017;34(14):2206–2219.27198861
32 Mac Donald CL, Johnson AM, Wierzechowski L, . Prospectively assessed clinical outcomes in concussive blast vs nonblast traumatic brain injury among evacuated US military personnel. JAMA Neurol. 2014;71(8):994–1002.24934200
33 MacDonald CL, Johnson AM, Nelson EC, . Functional status after blast-plus-impact complex concussive traumatic brain injury in evacuated United States military personnel. J Neurotrauma. 2014;31(10):889–898.24367929
34 MacGregor AJ, Dougherty AL, Tang JJ, Galarneau MR. Postconcussive symptom reporting among US combat veterans with mild traumatic brain injury from Operation Iraqi Freedom. J Head Trauma Rehabil 2013;28(1):59–67.22688214
35 MacGregor AJ, Shaffer RA, Dougherty AL, . Prevalence and psychological correlates of traumatic brain injury in operation iraqi freedom. J Head Trauma Rehabil. 2010;25(1):1–8.20051901
36 Mora AG, Ritenour AE, Wade CE, Holcomb JB, Blackbourne LH, Gaylord KM. Posttraumatic stress disorder in combat casualties with burns sustaining primary blast and concussive injuries. J Trauma. 2009;66:(4 Suppl):S178–185.19359963
37 Pietrzak RH, Johnson DC, Goldstein MB, Malley JC, Southwick SM. Posttraumatic stress disorder mediates the relationship between mild traumatic brain injury and health and psychosocial functioning in veterans of Operations Enduring Freedom and Iraqi Freedom. J Nerv Ment Dis. 2009;197(10):748–753.19829203
38 Polusny MA, Kehle SM, Nelson NW, Erbes CR, Arbisi PA, Thuras P. Longitudinal effects of mild traumatic brain injury and posttraumatic stress disorder comorbidity on postdeployment outcomes in national guard soldiers deployed to Iraq. Arch Gen Psychiatry. 2011;68(1):79–89.21199967
39 Tsai J, Whealin JM, Scott JC, Harpaz-Rotem I, Pietrzak RH. Examining the relation between combat-related concussion, a novel 5-factor model of posttraumatic stress symptoms, and health-related quality of life in Iraq and Afghanistan veterans. J Clin Psychiatry. 2012;73(8):1110–1118.22781019
40 Vanderploeg RD, Nazem S, Brenner LA, Belanger HG, Donnell AJ, Scott SG. Suicidal Ideation among Florida National Guard Members: Combat Deployment and Non-Deployment Risk and Protective Factors. Arch Suicide Res. 2015;19(4):453–471.25517207
41 Walker WC, Franke LM, Sima AP, Cifu DX. Symptom trajectories after military blast exposure and the influence of mild traumatic brain injury. J Head Trauma Rehabil. 2017;32(3):E16–E26.
42 Wilk JE, Herrell RK, Wynn GH, Riviere LA, Hoge CW. Mild traumatic brain injury (concussion), posttraumatic stress disorder, and depression in U.S. soldiers involved in combat deployments: association with postdeployment symptoms. Psychosomatic Medicine. 2012;74(3):249–257.22366583
43 Yurgil KA, Barkauskas DA, Vasterling JJ, . Association between traumatic brain injury and risk of posttraumatic stress disorder in active-duty Marines. JAMA Psychiatry. 2014;71(2):149–157.24337530
44 Bomyea JA, Lang AJ, Schnurr PP. TBI and treatment response in a randomized trial of Acceptance and Commitment Therapy. J Head Trauma Rehabil. 2017;32(5):E35–E43.
45 Chard KM, Schumm JA, McIlvain SM, Bailey GW, Parkinson RB. Exploring the efficacy of a residential treatment program incorporating cognitive processing therapy-cognitive for veterans with PTSD and traumatic brain injury. J Trauma Stress. 2011;24(3):347–351.21626573
46 Harch PG, Andrews SR, Fogarty EF, . A phase I study of low-pressure hyperbaric oxygen therapy for blast-induced post-concussion syndrome and post-traumatic stress disorder. J Neurotrauma. 2012;29(1):168–185.22026588
47 Ragsdale KA, Voss Horrell SC. Effectiveness of prolonged exposure and cognitive processing therapy for U.S. Veterans with a history of traumatic brain injury. J Trauma Stress. 2016;29(5):474–477.27681034
48 Sripada RK, Rauch SA, Tuerk PW, . Mild traumatic brain injury and treatment response in prolonged exposure for PTSD. J Trauma Stress. 2013;26(3):369–375.23696427
49 Wolf GK, Kretzmer T, Crawford E, . Prolonged Exposure Therapy With Veterans and Active Duty Personnel Diagnosed With PTSD and Traumatic Brain Injury. J Trauma Stress. 2015;28(4):339–347.26201688
50 Wolf GK, Strom TQ, Kehle SM, Eftekhari A. A preliminary examination of prolonged exposure therapy with Iraq and Afghanistan veterans with a diagnosis of posttraumatic stress disorder and mild to moderate traumatic brain injury. J Head Trauma Rehabil. 2012;27(1):26–32.22218201
51 Monson CM, Gradus JL, Young-Xu Y, Schnurr PP, Price JL, Schumm JA. Change in posttraumatic stress disorder symptoms: do clinicians and patients agree? Psychol Assess. 2008;20(2):131–138.18557690
52 Shiner B, Watts BV, Pomerantz AS, Young-Xu Y, Schnurr PP. Sensitivity of the SF-36 to PTSD symptom change in Veterans. J Trauma Stress. 2011;24(1):111–115.21351169
53 Stefanovics EA, Rosenheck RA, Jones KM, Huang G, Krystal JH. Minimal clinically important differences (MCID) in assessing outcomes of post-traumatic stress disorder. Psychiatr Q. 2018;89:141–155.28634644
54 Schnurr PP, Lunney CA. Symptom benchmarks of improved quality of life in PTSD. Depress Anxiety. 2016;33:247–255.26882293
55 Button KS, Kounali D, Thomas L, . Minimal clinically important difference on the Beck Depression Inventory - II according to the patient’s perspective. Psychol Med. 2015;48(3269–3279).
56 Peterson K, Bourne D, Anderson J, Boundy E, Helfand M. Evidence Brief: Hyperbaric Oxygen Therapy (HBOT) for Traumatic Brain Injury and/or Post-traumatic Stress Disorder. Washington (DC): Department of Veterans Affairs (US). https://www.ncbi.nlm.nih.gov/books/NBK499535/. Published March 2018. Accessed April 6, 2018.
57 Epidemiology Program, Post-Deployment Health Group, Office of Patient Care Services, Veterans Health Administration, Department of Veterans Affairs. Analysis of VA Health Care Utilization among Operation Enduring Freedom, Operation Iraqi Freedom, and Operation New Dawn Veterans, from 1st Qtr FY 2002 through 3rd Qtr FY 2015. https://www.publichealth.va.gov/epidemiology/reports/oefoifond/health-care-utilization/index.asp. Published 2015, Accessed May 3, 2018.
58 Baker DG, Nash WP, Litz BT, . Predictors of risk and resilience for posttraumatic stress disorder among ground combat Marines: methods of the Marine Resiliency Study. Prev Chronic Dis. 2012;9:110134.
59 Gray GC, Chesbrough KB, Ryan MA, . The Millennium Cohort Study: a 21-year prospective cohort sutdy of 140,000 military personnel. Mil Med. 2002;167(6):483–488.12099084
60 Rosen RC, Marx BP, Maserejian NN, . Project VALOR: design and methods of a longitudinal registry of post-traumatic stress disorder (PTSD) in combat-exposed Veterans in the Afghanistan and Iraqi military theaters of operations. Int J Methods Psychiatr Res. 2012;21(1):5–16.22095917
61 Vasterling JJ, Aslan M, Proctor SP, . Longitudinal examination of posttraumatic stress disorder as a long-term outcome of Iraq War deployment. Am J Epidemiol. 2016;184(11):796–805.27852604
62 Donnelly KT D, J.P.; Dunnam, M.; . Reliability, Sensitivity, and Specificity of the VA Traumatic Brain Injury Screening Tool. J Head Trauma Rehabil. 2011;26(6):439–453.21386716