# Results

## Literature Flow

After removing 245 duplicate citations, we screened 1,215 abstracts (Figure 1). We excluded 740 records leaving 475 citations for full text review. An additional 434 references were excluded resulting in 41 included articles (34 articles representing 33 studies for Key Question 1 and 7 articles for Key Question 2).

Figure 1 Literature Flow Chart

## KEY QUESTION 1A Is the prevalence of psychiatric conditions (posttraumatic stress disorder [PTSD], depressive disorders, substance use disorders, suicidal ideation or attempts, and anxiety disorders) different in service members and Veterans with and without deployment-related mild traumatic brain injury (mTBI) (one or more)?

## KEY QUESTION 1B How do severity and persistence of psychiatric conditions (PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, and anxiety disorders) differ in service members and Veterans with and without deployment-related mTBI?

### Overview of Included Studies

We identified 33 unique studies in 34 articles that reported prevalence and/or symptom severity and persistence of PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, or anxiety disorders in OEF/OIF/OND service members or Veterans with and without deployment-related TBI, predominantly mTBI. Table 1 summarizes the studies. There were 11 studies that reported data from a national sample^10–20^ and 22 studies (in 23 articles) where data were collected from a geographically diverse sample including multiple sites (eg, multiple Veterans medical centers) or individuals that represented a broader population than would be found at a single medical center (eg, a military base in Iraq or a National Guard Brigade Combat Team).^21–43^ Four of the national sample studies^10,11,13,20^ and 7 of the geographically diverse sample studies^26,28,29,35–38^ specified that the purpose of the study was to report prevalence of the psychiatric conditions.

Among the 11 national sample studies, 4 studies enrolled service members. Two of the 4 studies included US Army^10^ or US Army Special Operations Command personnel^16^ deployed between 2008 and 2011. Another study included service members from all branches deployed from 2008 to 2010.^15^ The fourth study included Navy sailors and Marines deployed from 2008 to 2009.^17^ It is unclear whether there is duplication of the samples across studies. Of the 7 national sample studies enrolling Veterans, 4 included all Veterans using VHA care during time periods of 1 to 5 years between 2007 and 2014.^11,14,19,20^ Additionally, 2 studies included Veterans who had completed the VA Comprehensive TBI Evaluation (CTBIE) between 2007 and 2012^12,18^ and the seventh study included Veterans who received alcohol screening in 2012.^13^ Thus, all of the studies of Veterans included samples from the population of VA users between 2007 and 2014.

One of the national sample studies included only service members with a history of mTBI,^16^ one included any TBI severity with 83% mTBI,^15^ and 2 did not specify TBI severity.^10,17^ Of the 7 studies enrolling OEF/OIF/OND Veterans, 2 reported on Veterans with a history of mTBI,^18,19^ one included any TBI severity with 88% mTBI,^12^ and 4 did not specify TBI severity. Accurate information on TBI severity can be difficult to obtain from administrative records commonly used to obtain nationally representative samples.

Sample sizes ranged from 9,258 to 684,133. Only one study reported time since TBI, a mean of 4.8 years.^11^ Four studies reported TBI etiology including 100% blast injury,^17^ 74% to 80% blast or blast plus other cause,^12,18^ and 60% blunt force trauma.^16^ Three studies obtained data from medical records,^12,14,15^ 3 obtained data from surveys/questionnaires,^10,16,17^ and 5 obtained data from administrative databases.^11,13,18–20^ Complete study characteristics and outcomes data are presented in Appendix C, Table 1.

Of the 22 geographically diverse studies, 15 enrolled service members,^22–25,28,29,31–36,38,40,42,43^ 6 enrolled Veterans,^21,26,27,30,37,39^ and one included both Veterans and service members.^41^ Four of the studies enrolling service members included only Army members.^22,29,38,42^ Three studies included more than 75% Army members,^23,24,32,33^ 2 studies included more than 75% Marine Corps members,^28,35^ and the remaining studies were either mixed or did not specify service branch. Sample sizes ranged from 65 to 11,828 with 15 enrolling fewer than 1,000. The studies of service members all enrolled only individuals with a history of mTBI with the exception of one study where 87% had a history of mTBI.^43^ Four studies of Veterans and the study of service members and Veterans enrolled only individuals with a history of mTBI^21,27,37,39,41^; 2 studies did not specify TBI severity but was presumed to be largely mTBI.^26,30^

Nine studies reported time since TBI with mean or median values of less than 14 days in 5 studies,^23–25,31–33^ less than 1 year in 3 studies,^36,41,43^ and greater than 1 year in one study.^21^ Three studies reported time from last deployment (4 to 6 months,^42^ 23 months,^37^ and 32 months^40^) and one reported time since discharge (430 days^26^). TBI etiology included exclusively blast exposure in 5 studies^25,28,33,36,41^ and 65% to 95% of participants with blast exposure in 6 studies.^26,29,32,34,35,38^ Seven studies evaluated service members at a medical facility, 3 used administrative/database data, and 12 obtained data from self-report or interview. Additional information is presented in Appendix C, Table 2.

Of the 11 studies of national samples, one was rated low risk of bias, 9 as moderate risk of bias, and one as moderate-to-high risk of bias (Appendix C, Table 3). Of the 22 studies of geographically diverse samples, one was rated low risk of bias, 16 as moderate risk of bias, 3 as moderate-to-high risk of bias, and 2 as high risk of bias.

PTSD prevalence was the most frequently reported outcome – reported in 24 of 33 studies (Table 1). Nine studies reported PTSD symptom scores. Prevalence of depressive disorders was reported in 14 studies; 7 reported depressive symptom scores. The prevalence of substance use disorders (including alcohol, drug, and tobacco abuse) was reported by 12 studies with 4 reporting symptom scores. Fewer studies reported on suicidal ideation (2 prevalence, 1 symptom scores with 1 additional study reporting on suicide attempts) or anxiety disorders (7 prevalence, 1 symptom scores).

Table 1 Overview of Prevalence and Severity/Persistence Studies (KQ1a/1b)

Author, year | Sample (Primary Data Source) or Site | Veteran or SM | Sample Size | mTBI or Unspecified TBI | PTSD | | Depressive Disorders | | Substance Use Disorders | | Suicidal Ideation | | Anxiety Disorders
Author, year | Sample (Primary Data Source) or Site | Veteran or SM | Sample Size | mTBI or Unspecified TBI | P | S | P | S | P | S | P | S | P | S
NATIONAL SAMPLES (k=11)
Kontos 2013^16^ | National (Web-based evaluation) | SM (Army Special Operations Command) | 22,203 | mTBI | | ✓
Johnson 2015^15^ | National (Medical records) | SM (41% Army, 22% Air Force, 21% Navy, 14% Marine Corps) | 162,898 | 83% mTBI, 6% moderate, 4% severe, 1% penetrating, 6% unclassified | | | | | ✓
Adams 2017^10^ | National (Post-deployment questionnaire) | SM (Army) | 267,100 | TBI | | | | | ✓
Macera 2012^17^ | National (Post-deployment questionnaire) | SM (75% Marine Corps, 25% Navy) | 9,902 | TBI | | | ✓
Pogoda 2016^18^ | National (CTBIE and Patient care databases) | Veteran | 9,337 | mTBI^a^ | ✓ | | ✓ | | ✓ | | | | ✓
Seal 2016^19^ | National (Patient care database) | Veteran | 66,089 | mTBI | ✓ | | ✓
Fonda 2017^12^ | National (Medical records) | Veteran | 273,591 | 88% mTBI, 6% moderate, 6% severe | ✓ | | ✓ | | ✓ | | ✓ | | ✓
Cifu 2013^11^ | National (Patient care database) | Veteran | 613,391 | TBI | ✓
Grossbard 2017^13^ | National (Corporate Data Warehouse) | Veteran | 358,147 | TBI | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Jaramillo 2015^14^ | National (VA inpatient and outpatient files) | Veteran | 303,716 | TBI | ✓ | | ✓
Taylor 2015^20^ | National (Corporate Data Warehouse) | Veteran | 684,133 | TBI | ✓ | | ✓ | | ✓ | | | | ✓
Subtotal (k=11) | | | | | 7 | 1 | 7 | 0 | 6 | 1 | 1 | 0 | 4 | 0
GEOGRAPHICALLY DIVERSE SAMPLES (k=22)
Brenner 2010^22^ | Brigade Combat Team (Questionnaire) | SM (Army) | 1,247 | mTBI | ✓
Bryan 2013^23,24^ | Combat support hospital (Iraq) outpatient TBI clinic (Interview) | SM (79% Army, 13% Air Force, 5% Marine Corps) | 158 | mTBI | | ✓ | | ✓ | | | ✓ | ✓
Bryant 2015^25^ | Combat theater hospital (Routine assessment) | SM (details not reported) | 685 | mTBI | ✓
Heltemes 2011^28^ | Forward-deployed medical treatment facilities (Database) | SM (77% Marine Corps, 17% Army, 5% Navy) | 3,123 | mTBI | | | | | ✓
Hoge 2008^29^ | Post-deployment survey | SM (Army) | 2,525 | mTBI | ✓ | ✓ | ✓
MacDonald 2014^33^ | Landstuhl Regional Medical Center (Germany) (Clinical assessment) | SM (88% Army, 9% Marine Corps, 3% Air Force) | 65 | mTBI | ✓ | ✓ | ✓ | ✓
MacDonald 2014^32^ | Landstuhl Regional Medical Center (Germany) (Clinical assessment) | SM (85% Army, 8% Air Force, 7% Marine Corps, <1% Navy) | 178 | mTBI | ✓ | ✓ | | ✓ | | ✓
MacDonald 2017^31^ | Landstuhl Regional Medical Center (Germany) (Clinical assessment) | SM (62% Army, 22% Navy, 13% Marine Corps, 3% Air Force) | 72 | mTBI | | ✓ | | ✓
MacGregor 2013^34^ | EMED (Database and questionnaire) | SM (57% Marine Corps, 33% Army, 9% Other) | 992 | mTBI | ✓ | | ✓
MacGregor 2010^35^ | EMED (Database) | SM (76% Marine Corps, 20% Army, 9% Other) | 762 | mTBI^a^ | ✓ | | | | ✓ | | | | ✓
Mora 2009^36^ | US Army Institute of Surgical Research Burn Center (Database) | SM | 110 | mTBI | ✓
Polusny 2011^38^ | Army National Guard Brigade Combat Team (Questionnaire) | SM (Army) | 937 | mTBI | ✓ | ✓ | | ✓ | | ✓
Vanderploeg 2015^40^ | Florida National Guard (Survey) | SM (Branch not reported) | 1,443 | mTBI | ✓ | | ✓ | | ✓ | | ✓
Wilk 2012^42^ | Brigade Combat Teams (Questionnaire) | SM (Army) | 1,502 | mTBI | ✓ | | ✓
Yurgil 2014^43^ | Southern California infantry battalions (Interview) | SM (Marine Corps and Navy | 1,648 | 87% mTBI, 1% unknown, 12% severity not reported | ✓
Baldassarre 2015^21^ | VA Polytrauma Network Sites (Interview) | Veteran | 396 | mTBI | ✓ | | ✓ | | ✓ | | | | ✓
Gaines 2016^27^ | VA Clinics in California (Questionnaire) | Veteran | 114 | mTBI | | | | ✓
Pietrzak 2009^37^ | Connecticut Department of Veterans Affairs (Survey) | Veteran | 277 | mTBI | ✓
Tsai 2012^39^ | VA Hawaii Program Registry for OEF/OIF/OND (Survey) | Veteran | 233 | Concussion | ✓ | | | | ✓
Carlson 2010^26^ | VA Medical Centers and clinics in VISN 23 (Administrative data) | Veteran | 11,828 | TBI | ✓ | | ✓ | | ✓ | | | | ✓
King 2017^30^ | VA Medical Centers and clinics in upstate New York (Interview) | Veteran | 291 | TBI | ✓ | ✓ | | | | ✓
Walker 2017^41^ | VA Medical Center and 3 Military Bases (Interview and questionnaire) | Veteran & SM (1 Army base, 2 Marine Corps bases) | 216 | mTBI | | ✓ | | ✓
Subtotal (k=22) | | | | | 17 | 8 | 7 | 7 | 6 | 3 | 2 | 1 | 3 | 0
TOTAL (k=33) | | | | | 24 | 9 | 14 | 7 | 12 | 4 | 3 | 1 | 7 | 0

a Reported data separately for mTBI and moderate/severe TBI; only mTBI data included in this review

CTBIE=Comprehensive TBI Evaluation; EMED=Expeditionary Medical Encounter Database); mTBI=mild traumatic brain injury; P=Prevalence of Psychiatric Conditions; PTSD=posttraumatic stress disorder; S=Severity or Persistence based on Symptom Scores; SM=Service Members (active duty); TBI=traumatic brain injury; VISN=Veterans Integrated Service Network

### PTSD

#### National Samples

##### Prevalence

Seven studies of Veterans reported PTSD prevalence (Table 2, Appendix C, Table 1).^11–14,18–20^ There were no reports of PTSD prevalence in the studies of active duty service members. In 6 studies, the prevalence was based on International Classification of Diseases, Ninth Revision (ICD-9) codes;^11–14,19,20^ one obtained data from the checklist clinicians complete as part of the VA’s Comprehensive Traumatic Brain Injury Evaluation (CTBIE).^18^ All of the studies reported a higher prevalence of PTSD in individuals with a history of mTBI or TBI unspecified (Table 2). The percentage of individuals with a PTSD diagnosis in the history of TBI groups ranged from 63% to 77%; the percentage in the no-TBI groups ranged from 10% to 64% (moderate strength evidence, Table 3). In all but one study^19^ the difference in prevalence between the TBI and no-TBI groups was at least 20%.

##### Severity/Persistence

One study of active duty service members also reported Posttraumatic Stress Disorder Checklist (PCL) scores (version not reported), an assessment of PTSD symptom severity, for the mTBI and no-TBI groups.^16^ In the mTBI group, the mean scores were 20.3 for those with a blunt injury, 22.6 for those with a blast-related injury, and 24.3 for those with a combination of blast and blunt injury. The mean PCL score in the no-TBI group was 18.4. The authors noted that none of the scores met suggested cut scores for PTSD diagnosis (Appendix C, Table 1).

#### Geographically Diverse Samples

##### Prevalence

Seventeen geographically diverse studies reported prevalence of PTSD (Table 4, Appendix C, Table 2). Nine studies used PCL scores (5 PCL-M, 1 PCL-C, 1 PCL-17, 2 version not reported; cut points varied), 4 used Clinician Administered PTSD Scale for Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition (CAPS-IV) scores, 2 used ICD-9 codes, one used the Primary Care-Posttraumatic Stress Disorder (PC-PTSD) screen, and one used Post Deployment Health Assessment (PDHA) data to identify PTSD cases. Among the 12 studies of service members reporting PTSD prevalence, 9 found higher prevalence in the group with a history of mTBI.^22,25,29,33,34,38,40,42,43^ Two studies reported similar prevalence in the history of mTBI and no-TBI groups, one based on PCL-M cut-off scores^36^ and the other on ICD-9 codes.^35^ One study reported mixed results. There was a similar prevalence of service members meeting criteria for PTSD (CAPS-IV) in the blast-related mTBI and blast-exposed control (no-TBI) groups but a higher prevalence in the mTBI groups (either blast-related or non-blast-related) compared to the non-blast exposed control group.^32^ PTSD prevalence was reported in 5 of the 7 studies of Veterans – all reported higher prevalence in the groups with a history of mTBI^21,37,39^ or TBI unspecified.^26,30^

Table 2 Prevalence and Severity/Persistence of Psychiatric Conditions in Veterans and Service Members with and without Deployment-related TBI – National Samples

Author, year; Study Characteristics; Study Period | Prevalence | | | | | Severity/Persistence
Author, year; Study Characteristics; Study Period | PTSD | Depressive disorders | Substance Use Disorders | Suicidal Ideation | Anxiety Disorders | PTSD | Depressive disorders | Substance Use Disorders | Suicidal Ideation | Anxiety Disorders
SERVICE MEMBERS
Kontos, 2013^16^; N=22,203/mTBI; Nov 2009–Dec 2011 | | | | | | ↑
Johnson, 2015^15^; N=162,898/83% mTBI; 2008–2010 | | | ↑ Alcohol; ↑ Drug; ↑ Both
Adams, 2017^10^; N=267,100/TBI; FY 2008–2011 | | | ↑ Binge Drinking
Macera, 2012^17^; N=9,902/TBI; 2008–2009 | | ↑ ^a^
VETERANS
Pogoda, 2016^18^; N=9,337/mTBI; Oct 2007–June 2009 | ↑ | ↑ | ↔ Alcohol; ↔ Drug | | ↔
Seal, 2016^19^; N=66,089/mTBI; April 2007–May 2012 | ↑ | ↔
Fonda, 2017^12^; N=273,591/88% mTBI; April 2007–Sept 2012 | ↑ | ↑ | ↑ Alcohol; ↑ Other | ↑ Attempted | ↑
Cifu, 2013^11^; N=613,391/TBI; FY 2009–2011 | ↑
Grossbard, 2017^13^; N=358,147/TBI; 2012 | ↑ | ↑ | ↑ Alcohol; ↑ Drug; ↑ Tobacco | | ↑ | | | ↑ Alcohol
Jaramillo, 2015^14^; N=303,716/TBI; FY 2010–2011 | ↑ | ↑
Taylor, 2015^20^; N=684,133/TBI; FY 2014 | ↑ | ↑ | ↑ Substance; ↑ Nicotine | | ↑
TOTALS | ↑ 7 | ↑ 6; ↔ 1 | ↑ 5; ↔ 1 | ↑ 1 | ↑ 3; ↔ 1 | ↑ 1 | | ↑ 1

↑=Higher prevalence or severity in deployment-related TBI group compared to no deployment-related TBI group

↔=Similar prevalence or severity in deployment-related TBI group compared to no deployment-related TBI group

a Higher prevalence for TBI vs No TBI; difference was not significant for TBI Only (no PTSD) vs No TBI/No PTSD

FY=fiscal year; TBI=traumatic brain injury; mTBI=mild traumatic brain injury

Table 3 Strength of Evidence – Key Question 1

Key Question 1a: Prevalence of psychiatric conditions from national samples (k=11)
Condition | Number of studies | Strength of evidence | Comments
PTSD | 7 | Moderate | - Risk of bias for these observational studies was generally moderate; - Different measures and criteria for psychiatric conditions were reported. Severity of TBI often unspecified (based on ICD-9 code); - Estimates of the prevalence of mental conditions were consistently higher in Veterans or active duty personnel with history of TBI. Wider variation in estimates observed for depressive, substance use, and anxiety disorders; - Wider variation in estimates of prevalence observed in those with no history of TBI; - Precision of estimates difficult to determine
Depressive disorders | 7 | Low
Substance use disorders | 6 | Low
Suicidal ideation | 0 | Insufficient
Anxiety disorders | 4 | Low
Key Question 1b: Severity of psychiatric conditions from national samples (k=11)
PTSD | 1 | Insufficient overall | - Severity of symptoms rarely reported
Depressive disorders | 0 | Insufficient overall | - Severity of symptoms rarely reported
Substance use disorders | 1 | Insufficient overall | - Severity of symptoms rarely reported
Suicidal ideation | 0 | Insufficient overall | - Severity of symptoms rarely reported
Anxiety disorders | 0 | Insufficient overall | - Severity of symptoms rarely reported

ICD-9=International Classification of Diseases, Ninth Revision; PTSD=posttraumatic stress disorder; TBI=traumatic brain injury

Table 4 Prevalence and Severity/Persistence of Psychiatric Conditions in Veterans and Service Members with and without Deployment-related TBI – Geographically Diverse Samples

Author, year; Study Characteristics | Prevalence | | | | | Severity/Persistence
Author, year; Study Characteristics | PTSD | Depressive Disorders | Substance Use Disorders | Suicidal Ideation | Anxiety Disorders | PTSD | Depressive Disorders | Substance Use Disorders | Suicidal Ideation | Anxiety Disorders
SERVICE MEMBERS
Brenner 2010^22^; N=1,247/mTBI | ↑
Bryan 2013 ^23,24^; N=158/mTBI | | | | ↑ | | ↑ | ↑ | | ↑
Bryant 2015^25^; N=685/mTBI | ↑
Heltemes 2011^28^; N=3,123/mTBI | | | ↔
Hoge 2008^29^; N=2,525/mTBI | ↑ LOC; ↑ AS | ↑ LOC; ↔ AS | | | | ↑ LOC; ↑ AS
MacDonald 2014^33^; N=65/mTBI | ↑ | ↔ | | | | ↑ | ↔
MacDonald 2014^32^; N=178/mTBI | ↔ Blast mTBI vs Blast/no TBI; ↑ Non Blast mTBI vs Non Blast/no TBI | | | | | ↔ Blast mTBI vs Blast/no TBI; ↑ Non Blast mTBI vs Non Blast/no TBI | ↔ Blast mTBI vs Blast/no TBI; ↑ Non Blast mTBI vs Non Blast/no TBI | ↔ Blast mTBI vs Blast/no TBI; ↔ Non Blast mTBI vs Non Blast/no TBI
MacDonald 2017^31^; N=72/mTBI | | | | | | ↑ | ↑
MacGregor 2013^34^; N=963/mTBI | ↑ | ↑
MacGregor 2010^35^; N=762/mTBI | ↔ mTBI vs Other Head Injury; ↔ mTBI vs Non-Head Injury | | ↔ mTBI vs Other Head Injury; ↔ mTBI vs Non-Head Injury | | ↔ mTBI vs Other Head Injury; ↔ mTBI vs Non-Head Injury
Mora 2009^36^; N=110/mTBI | ↔
Polusny 2011^38^; N=937/mTBI | ↑ | | | | | ↑ mTBI vs no TBI/no PTSD; ↔ mTBI/PTSD vs PTSD | ↑ mTBI vs no TBI/no PTSD; ↔ mTBI/PTSD vs PTSD | ↑ mTBI vs no TBI/no PTSD; ↔ mTBI/PTSD vs PTSD
Vanderploeg 2015^40^; N=1,443/mTBI | ↑ | ↑ | ↑ | ↑
Wilk 2012^42^; N=1,502/mTBI | ↑ LOC; ↑ AOC | ↑ LOC; ↑ AOC
Yurgil 2014^43^; N=1,648/87% mTBI | ↑ CAPS-IV ≥65; ↑ CAPS-IV 40–64
VETERANS
Baldassarre 2015^21^; N=396/mTBI | ↑ | ↑ | ↑ | | ↑
Gaines 2016^27^; N=114/mTBI | | | | | | | ↑
Pietrzak 2009^37^; N=277/mTBI | ↑
Tsai 2012^39^; N=233/Concussion | ↑ | | ↑
Carlson 2010^26^; N=11,828/TBI | ↑ | ↑ | ↑ | | ↑
King 2017^30^; N=291/TBI | ↑ | | | | | ↑ | | ↓
SERVICE MEMBERS AND VETERANS
Walker 2017^41^; N=216/mTBI | | | | | | ↑ Baseline; ↑ 12 months | ↑ Baseline; ↔ 12 months
TOTALS | ↑14; ↔2; Mixed 1 | ↑5; ↔1; Mixed 1 | ↑4; ↔2 | ↑2 | ↑2; ↔1 | ↑6; Mixed 2 | ↑4; ↔1; Mixed 2 | ↓1; ↔1; Mixed 1 | ↑1 | NR

↑=Higher prevalence or severity in deployment-related TBI group compared to no deployment-related TBI group

↓=Lower prevalence or severity in deployment-related TBI group compared to no deployment-related TBI group

↔=Similar prevalence or severity in deployment-related TBI group compared to no deployment-related TBI group

AOC=alteration of consciousness; AS=altered state; CAPS-IV=Clinician Administered PTSD Scale for DSM-IV; LOC=loss of consciousness; PTSD=posttraumatic stress disorder; TBI=traumatic brain injury; mTBI=mild traumatic brain injury

##### Severity/Persistence

Eight studies reported PTSD severity, 5 based on PCL^29,30,41^ or PCL-Military Version (PCL-M)^23,24,38^ total scores and 3 based on CAPS-IV scores.^31–33^ Six studies, 4 enrolling active duty service members and 2 enrolling Veterans, found higher scores in the groups with a history of TBI of any severity or mTBI compared to no-TBI (Table 4, Appendix C, Table 2). One of these studies reported that higher mean PCL total scores (version not reported) in the history of mTBI group persisted at 12 months.^41^ Two studies reported mixed results depending on the comorbidity or TBI etiology. Among service members with no probable PTSD assessed 1 year following deployment, Polusny et al. observed higher PCL-M scores for the group with a history of mTBI compared to the group with no history of TBI. Among service members with probable PTSD, the presence of a mTBI was not associated with greater severity of PTSD symptoms.^38^ MacDonald observed higher CAPS-IV scores in service members with non-blast injury mTBI compared to the no-TBI group but similar scores for the blast injury mTBI group compared to the no-TBI group.^31^

### Depressive Disorders

#### National Samples

##### Prevalence

The prevalence of depressive disorders was reported in 6 studies of Veterans^12–14,18–20^ and one study of active duty service members (Table 2, Appendix C, Table 1).^17^ As with the PTSD data, most prevalence information was obtained from ICD-9 codes. One study used 2 items from the Patient Health Questionnaire^17^ and one used clinical report from the checklist embedded in the CTBIE.^18^ Six studies reported a higher prevalence of depressive disorders in the history of mTBI or TBI unspecified groups (31% to 50%) than in the no-TBI groups (11% to 35%).^12–14,17,18,20^ The differences in prevalence ranged from 5% to 37%. One of these studies noted that the prevalence of depressive disorders was similar in the TBI and no-TBI groups if the TBI group was limited to those with no PTSD but higher in the TBI with PTSD group compared to the no TBI and no PTSD group.^17^ The remaining study found a similar prevalence of depressive disorder in Veterans with a history of mTBI (47%) or no-TBI (45%) (low strength evidence, Table 3).^19^

##### Severity/Persistence

None of the national sample studies reported severity or persistence of depressive disorders.

#### Geographically Diverse Samples

##### Prevalence

Seven geographically diverse sample studies reported prevalence of depressive disorders. Three studies of service members and 2 studies of Veterans reported higher prevalence of depressive disorders in the groups with a history of TBI unspecified^26^ or mTBI^21,34,40,42^ (Table 4, Appendix C, Table 2). The findings were based on the Patient Health Questionnaire – 9 item (PHQ-9),^40,42^ the Post Deployment Health Reassessment (PDHRA),^34^ Beck Depression Index-II (BDI-II),^21^ and ICD-9 codes.^26^ One study, based on Patient Health Questionnaire – 15 item (PHQ-15) scores found mixed results among service members with higher prevalence in those with a history of mTBI with a loss of consciousness compared to those with other injury (ie, injury with no loss of consciousness or altered mental status) and a similar prevalence in those with a history of mTBI with altered mental status compared to those with other injury.^29^ MacDonald found the prevalence of depressive disorders, based on MADRS scores, was similar in service members with and without a history of mTBI.^31^

##### Severity/Persistence

Four studies reported higher depressive symptom scores in the groups with a history of mTBI vs no-TBI (Table 4, Appendix C, Table 2). Two of these studies enrolled service members,^23,24,31^ one enrolled Veterans,^27^ and one enrolled both service members and Veterans.^41^ They used different measures of depressive symptoms – the Behavioral Health Measures-20 item,(BHM-20)^23,24^ the Montgomery-Asberg Depression Rating Scale (MADRS),^31^ the BDI-II.^27^ and the Center for Epidemiologic Studies Depression (CESD) scale.^41^ One of these studies re-assessed outcomes at 12 months and found no difference between groups.^41^

Two other studies reported mixed results depending on comorbidity and TBI etiology. Consistent with what the same authors observed regarding PTSD severity, Polusny observed higher BDI-II scores for the mTBI group compared to the group with no history of TBI and no PTSD but similar scores when the group with comorbid mTBI and PTSD was compared to the PTSD only group.^38^ MacDonald observed higher MADRS scores in service members with non-blast injury mTBI compared to the no-TBI group but similar scores for the blast injury mTBI group compared to the no-TBI group.^31^ The last study observed no differences in MADRS scores among service members with and without a history of mTBI.^33^

### Substance Use Disorders

#### National Samples

##### Prevalence

Two studies of active duty service members^10,15^ and 4 studies of Veterans^12,13,18,20^ reported on prevalence of substance use disorders in those with and without TBI unspecified^10,15^ ^13,20^ or mTBI^12,18^(Table 2, Appendix C, Table 1). One study of service members presented data on self-reported binge drinking obtained from the PDHA. The rate of binge drinking was found to be higher in the group with TBI (28%) vs no-TBI group (19%).^10^ The other study of service members reported prevalence values for alcohol use disorder, other drug use disorder, and combined alcohol and other drug use disorders obtained with ICD-9 codes.^15^ The overall percentages for each of the 3 disorders were low (4% or less in the mTBI groups and 2% or less in the no TBI groups) with higher values consistently found for the mTBI group compared to the no TBI group.

The studies of Veterans reported data based ICD-9 codes^12,13,20^ or the clinical report from the checklist embedded in the CTBIE.^18^ Two^12,13^ of 3 studies reporting alcohol abuse found higher prevalence in the mTBI or TBI unspecified groups (8% to 13%) compared to the no-TBI groups (4% to 11%); the third study, with data from the CTBIE, found similar prevalence of alcohol abuse in the mTBI and no-TBI groups.^18^ In another study, substance use disorders (excluding nicotine dependence) were higher in the TBI group compared to the no-TBI group (38% vs 21%).^20^ Substance-use disorder other than alcohol or tobacco^12^ or drug abuse^13^ were higher in the mTBI or TBI unspecified groups in 2 of the 3 studies reporting.^12,13^ As with alcohol dependence, the study with data from the CTBIE checklist found similar prevalence of drug abuse in the mTBI and no-TBI groups.^18^ Tobacco abuse was higher in the TBI groups (25% in 2 studies) than the no-TBI group (14% to 19%) (low strength evidence, Table 3).^13,20^

##### Severity/Persistence

One study reported severity of alcohol misuse based on Alcohol Use Disorders Identification Test-Consumption (AUDIT-C) scores (Table 2, Appendix C, Table 1).^13^ There was a higher percentage of moderate alcohol abuse (AUDIT-C of 5 to 7) and severe alcohol abuse (AUDIT-C of 8 to 12) in the TBI group. The percentages were 11% in the TBI vs 9% in the no TBI group for moderate alcohol abuse and 8% in the TBI vs 6% in the no TBI group for severe alcohol abuse.

#### Geographically Diverse Samples

##### Prevalence

Six studies reported prevalence of substance use disorders (Table 4, Appendix C, Table 2). Four studies found a higher prevalence of alcohol abuse in the groups with a history of TBI unspecified^26^ or mTBI^21,39,40^ compared to no TBI. Three of these studies enrolled Veterans^21,26,39^ and one enrolled service members.^40^ Outcomes were based on the AUDIT,^21,40^ Cutting down, Annoyance by criticism, Guilty feeling, and Eye openers (CAGE),^39^ or ICD-9 codes.^26^ Two studies, both based on ICD-9 codes, reported a similar prevalence of either alcohol abuse^28^ or any substance disorder^35^ in service members with and without a history of mTBI.

##### Severity/Persistence

Scores from measures of alcohol misuse were reported by 3 studies (Table 4, Appendix C, Table 2). King reported lower AUDIT-C scores in Veterans with a history of TBI compared to no-TBI although mean scores for both groups indicated potentially hazardous alcohol intake.^30^ Polusny reported higher AUDIT scores for service members in the mTBI group compared to the group with no history of TBI and no PTSD but similar scores when the group with comorbid mTBI and PTSD was compared to the PTSD only group.^38^ MacDonald reported that Michigan Alcohol Screening Test (MAST) scores were similar for service members who experienced a blast-related TBI, a non-blast related TBI, blast exposed controls, and non-blast exposed controls.^32^

### Suicidal Ideation or Attempts

#### National Samples

##### Prevalence

None of the included studies reported on prevalence of suicidal ideation (insufficient evidence, Table 3). One study provided data on attempted suicides among Veterans defined using ICD-9 codes for suicide and self-inflicted injury recorded during an emergency department visit or hospitalization (Table 2, Appendix C, Table 1).^12^ There was a greater prevalence in the Veterans with a history of TBI (0.5% vs 0.1%).

##### Severity/Persistence

No study reported scores from a measure that assesses suicidal ideation.

#### Geographically Diverse Samples

##### Prevalence

Two studies of active duty service members reported higher prevalence of suicidal ideation in the groups with a history of mTBI (Table 4, Appendix C, Table 2). Ideation was assessed using the Suicide Behaviors Questionnaire – Revised (SBQ-R)^23,24^ or a single item from the PHQ-9 that asks frequency of experiencing “thoughts that you would be better off dead, or of hurting yourself”.^40^

##### Severity/Persistence

One study reported higher scores on the SBQ-R in service members with a history of mTBI compared to no-TBI (Table 4, Appendix C, Table 2).^23,24^

### Anxiety Disorders

#### National Samples

##### Prevalence

Four studies of Veterans reported prevalence of anxiety disorders other than PTSD (Table 2, Appendix C, Table 1).^12,13,18,20^ Three studies, all using ICD-9 codes, reported higher prevalence of anxiety disorders in Veterans with a history of TBI unspecified^13,20^ or mTBI^12^ compared to no TBI. The prevalence in the TBI groups ranged from 17% to 31%; prevalence in the no-TBI groups ranged from 8% to 16%. The fourth study identified anxiety disorder using the clinical report from the checklist embedded in the CTBIE.^18^ Prevalence of anxiety disorder was similar: 24% in the TBI group and 26% in the no-TBI group (low strength evidence, Table 3).

##### Severity/Persistence

No study reported scores from a measure that assesses anxiety disorders.

#### Geographically Diverse Samples

##### Prevalence

Two studies of Veterans found higher prevalence of anxiety disorders in those with a history of TBI unspecified^26^ or mTBI^21^ compared to no-TBI (Table 4, Appendix C, Table 2). The findings were based on the Beck Anxiety Index (BAI)^21^ with scores of 8 and higher indicating mild to severe anxiety disorder and ICD-9 codes for anxiety disorders other than PTSD.^26^. A study of ICD-9 codes in active duty service members found similar prevalence of anxiety disorders including PTSD when the history of mTBI group was compared to a no-TBI head injury group and a non-head injury group.^35^

##### Severity/Persistence

No study reported scores from a measure that assesses anxiety disorders.

### Summary of Findings

We identified 11 studies of national samples and 22 studies of geographically diverse samples reporting prevalence and/or severity of PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, or anxiety disorders in OEF/OIF/OND service members or Veterans with a history of TBI compared to no history of TBI.

In 5 of the 11 national sample studies, participants had a history of mTBI; the remaining studies did not specify TBI severity. Four studies enrolled service members. It is unclear whether there is duplication of the samples across studies. All 7 of the national sample studies enrolling Veterans included samples from the population of VA users between 2007 and 2014.

Of the 22 geographically diverse sample studies, 20 focused on mTBI and 2 did not specify TBI severity. Studies varied widely in sample size, used different measures of the psychiatric conditions, and assessed mental health status at varying time points post injury.

Studies based on national samples and geographically diverse samples generally reported a higher prevalence (KQ1a) of PTSD and depressive disorders in service members and Veterans with a history of mTBI or TBI unspecified compared to no-TBI. National samples generally found a higher prevalence of substance use disorders in the service member and Veterans groups with a history of mTBI or TBI unspecified vs the no-TBI groups. Results for substance use disorders were mixed for the geographically diverse samples with several studies finding similar prevalence in service members with a history of mTBI compared to those with no TBI history. One national sample study of Veterans reported a higher prevalence of suicide attempts in Veterans with a history of mTBI. Two geographically diverse sample studies of service members reported the prevalence of suicidal ideation was higher in the mTBI groups compared to the no-TBI groups. National samples of Veterans using VHA care found a higher prevalence of anxiety disorders other than PTSD in the mTBI or TBI unspecified vs the no-TBI groups. One national sample of Veterans who completed the VA CTBIE found no difference in the prevalence of suspected symptoms of anxiety disorder other than PTSD in the mTBI and no-TBI groups. In geographically diverse samples, the prevalence of anxiety disorders was higher in Veterans with a history of mTBI or TBI unspecified. One study of service members found a similar prevalence of anxiety disorders including PTSD in the mTBI and no-TBI groups.

Strength of evidence based on data from the national samples was moderate for the prevalence of PTSD, low for the prevalence of depressive disorders, substance use disorders, and anxiety disorders and insufficient for the prevalence of suicidal ideation and severity of any of the psychiatric conditions (Table 3)

Two national sample studies reported severity or persistence of symptoms of the psychiatric conditions of interest. One study reported higher PCL (version not specified) scores in active duty service members with a history of mTBI although all PCL scores were below the suggested cut-off score for PTSD. Another study reported slightly higher percentages of both moderate and severe alcohol misuse in Veterans with a history of mTBI (insufficient evidence, Table 3).

In geographically diverse studies, PTSD severity scores were generally higher in the groups with a history of mTBI/TBI unspecified. Differences in symptom severity were less consistent for depressive and substance use disorders with studies reporting mixed results depending on injury type (blast or non-blast) or the comparison (mTBI vs no mTBI/no PTSD or mTBI/PTSD vs PTSD only). One study reported scores from a suicidal behavior measure that assessed ideation, threat of suicide attempt, and likelihood of suicidal behavior in the future, finding higher values in the service members with a history of mTBI. None of the geographically diverse studies reported anxiety severity in individuals with anxiety disorders.

## KEY QUESTION 2 What are the effectiveness and comparative effectiveness and harms of interventions for treatment of PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, and anxiety disorders in service members and Veterans with history of deployment-related mTBI?

### Overview of Studies - Randomized Controlled Trials

We found no randomized studies that evaluated the effectiveness of pharmacologic or behavioral therapies for the treatment of PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, and anxiety disorders in service members and Veterans with history of deployment-related mTBI.

### Overview of Studies - Non-randomized Studies

Seven non-randomized studies met eligibility criteria.^44–50^ Three studies compared treatment of a psychiatric condition of interest in service members or Veterans with a history of TBI to treatment of those without a history of TBI.^44,47,48^ Four studies exclusively explored treatments in service members or Veterans with a history of TBI.^45,46,49,50^

Six studies examined the effectiveness of behavioral therapies for PTSD, depressive, or anxiety disorders.^44,45,47–50^ Most were pre-treatment to post-treatment studies; two were secondary analyses of RCTs.^44,48^ Sample sizes ranged from 10 to 129. The studies included mostly Veterans, 78% to 100% male, with mean ages between 33 and 35 years and the majority Caucasian/white. Etiology of TBI and history of multiple TBIs were rarely reported. Additional population and study characteristics are presented in Appendix C, Table 4; outcomes are presented in Appendix C, Table 5. Risk of bias for these studies was mostly moderate-to-high (Appendix C, Table 6). Most of the studies did not assess or report treatment fidelity and independent outcome assessment was either not conducted or was unclear.

Hyperbaric oxygen therapy (HBO_2_) was evaluated in one small, proof-of-concept, pre-post study enrolling 16 male service members and Veterans (mean age 30 years) with PCS and PTSD and a history of mild to moderate blast-related TBI (Appendix C, Tables 4 and 5).^46^ Risk of bias was moderate (Appendix C, Table 6).

We report mean differences and effect sizes for pre- to post-treatment scores in groups with a history of TBI (Table 5) and effect sizes for the differences in mean change from baseline for studies reporting data for groups with a history of TBI and groups with no history of TBI (Table 6). The effect sizes should be interpreted with caution. In studies without a usual care or wait-list control group, it is difficult to assess the effect of the intervention. Strength of evidence for the treatment interventions is presented in Table 7.

#### Behavioral Therapies

##### Studies of Veterans with and without a History of TBI

One study included Cognitive Processing Therapy (CPT) and Prolonged Exposure Therapy (PE) groups.^47^ The study was retrospective, using clinical data collected during routine pre- and post-treatment assessments. TBI status was obtained from medical records; severity could not be determined. Both CPT (n=10) and PE (n=9) significantly reduced PTSD symptoms in Veterans with a history of TBI as assessed with the PCL-S (Table 5). Improvements in symptoms of depression, assessed with the BDI-II, were significant only in the PE group. The effect sizes were large with wide confidence intervals (lower confidence limit crossing an ES of 0.5) (insufficient evidence, Table 7). Improvements in PTSD and depressive symptoms were similar in those with a history of TBI (n=19), compared to those with PTSD only (n=22), for the CPT group, the PE group, and when data from both groups were combined indicating that a history of TBI did not affect treatment outcome (Table 6).

Another study included Acceptance and Commitment Therapy (ACT) and Present Centered Therapy (PCT) groups.^44^ The study was a secondary analysis (n=129) of a multisite RCT in male and female (22%) Veterans who met current criteria for at least one anxiety or depressive disorder (including PTSD) based on DSM-IV criteria.^44^ The study included Veterans with a history of mild to moderate TBI (64%, n=83) and those with no TBI (36%, n=46). TBI was assessed using the Injury and Traumatic Stress clinical consortium TBI screen. Symptoms of depression and anxiety were assessed with the Brief Symptom Inventory-18 (BSI-18). A T-score ≥ 63 (raw scores converted to age- and gender-normed T-scores) was considered clinical elevation. The BSI-18 T-scores at baseline for participants with a history of TBI in the PCT and ACT groups were 73 and 75, respectively and were comparable to those without a history of TBI (73 for both groups). At the post-treatment assessment, there were statistically significant but modest reductions (<10 point improvements) in the BSI-18 observed for both therapies in Veterans with and without a history of TBI, indicating treatment response did not differ between the TBI and non-TBI groups, regardless of the intervention (Tables 5 and 6). TBI did not moderate or predict post-treatment outcomes (insufficient evidence, Table 7). This study also assessed quality of life. There were modest but statistically significant improvements over time in Short Form 12 Health Survey mental health component scores in both treatment groups; physical health component scores did not change significantly. Treatment effects did not vary in Veterans with and without mild to moderate TBI.

The third study was a post-hoc analysis of an RCT enrolling Veterans receiving either PE or PCT at a VA PTSD specialty clinic.^48^ In 8 Veterans with PTSD and a history of mostly mild TBI receiving either PE or PCT, CAPS-IV scores were reduced from pre-treatment (Table 5) but the study did not report how many of the Veterans were in the PE or PCT groups, limiting interpretation of the effectiveness of the interventions (insufficient evidence, Table 7). There was no effect of TBI status when the Veterans with a history of mostly mild TBI (n=8) were compared to those with PTSD only (n=14).^48^ Mean change in scores from pre- to post-testing was similar between groups and an effect of TBI was not found (Table 6).

Table 5 Results from Treatment Studies in Service Members or Veterans with a History of TBI

Author, year; TBI severity; Setting | Therapy; Mean # sessions; N | Measures | Pre-treatment Score, mean (SD) | Post-treatment Score, mean (SD) | Change from Pre-treatment, mean | Effect Size (ES); [95%CI]; (Pre vs Post Treatment Scores)
Cognitive Processing Therapy (CPT) or Prolonged Exposure Therapy (PE)
Ragsdale 2016^47^ TBI severity unknown Outpatient | CPT; 12; N=10 | PCL-S | 59.30 (12.09) | 42.90 (13.84) | 16.40 | ES 1.21; [0.24 to 2.18]
Ragsdale 2016^47^ TBI severity unknown Outpatient | CPT; 12; N=10 | BDI-II | 26.10 (11.10) | 19.80 (15.02) | 6.30 | ES 0.46; [−0.43 to 1.35]
Ragsdale 2016^47^ TBI severity unknown Outpatient | PE; 10; N=9 | PCL-S | 62.67 (11.35) | 32.89 (15.98) | 29.78 | ES 2.05; [0.85 to 3.24]
Ragsdale 2016^47^ TBI severity unknown Outpatient | PE; 10; N=9 | BDI-II | 28.33 (15.22) | 12.11 (14.56) | 16.22 | ES 1.04; [0.04 to 2.04]
Acceptance and Commitment Therapy (ACT) or Present Centered Therapy (PCT)
Bomyea 2017^44^; Mild to moderate TBI; Outpatient | ACT; NR^a^; N=41 | BSI-18 | 73.29 (8.48) | NR | <10 points | ES not estimable, graphed data only
Bomyea 2017^44^; Mild to moderate TBI; Outpatient | PCT; NR^a^; N=42 | BSI-18 | 74.74 (7.73) | NR | <10 points | ES not estimable, graphed data only
PE Combined with PCT
Sripada 2013^48^; “Most” mTBI; Outpatient | PE and PCT; 10–12; N=8 | CAPS-IV | 82.4 (11.7) | 45.5 (32.5) | 36.90 | ES 1.43; [0.29 to 2.56]
Cognitive Processing Therapy (CPT)
Chard 2011^45^; mTBI; Residential (7 weeks) | CPT; 14; N=28^b^ | CAPS-IV | 75.14 (5.85) | 48.96 (22.29) | 26.18 | ES 1.58; [0.98 to 2.19]
Chard 2011^45^; mTBI; Residential (7 weeks) | CPT; 14; N=28^b^ | PCL-S | 61.82 (10.32) | 46.54 (16.11) | 15.28 | ES 1.11; [0.55 to 1.68]
Chard 2011^45^; mTBI; Residential (7 weeks) | CPT; 14; N=28^b^ | BDI-II | 32.64 (10.71) | 23.71 (10.98) | 8.93 | ES 0.81; [0.27 to 1.36]
Prolonged Exposure Therapy (PE)
Wolf 2015^49^; Mild-to-severe TBI; 78% Outpatient; 22% Inpatient | PE; 9.5; N=69 | PCL (version NR) | 64.75 (10.10) | 43.51 (16.81) | 21.24 | ES 1.52; [1.14 to 1.90]
Wolf 2015^49^; Mild-to-severe TBI; 78% Outpatient; 22% Inpatient | PE; 9.5; N=69 | BDI-II | 29.61 (9.49) | 18.07 (12.62) | 11.54 | ES 1.03; [0.67 to 1.38]
Wolf 2012^50^; 75% mTBI; Outpatient | PE; 13; N=10 | PCL-M | 69.2 (8.1) | 38.0 (9.0) | 31.20 | ES 3.49; [2.00 to 4.98]
Wolf 2012^50^; 75% mTBI; Outpatient | PE; 13; N=10 | BDI-II | 34.4 (9.7) | 17.7 (8.6) | 16.70 | ES 1.74; [0.68 to 2.81]

a Mean number of sessions completed in TBI group = 8.9 (not reported by intervention)

b Participants with a history of mTBI. An additional 14 had a history of moderate to severe TBI.

BDI-II=Beck Depression Inventory-II; BSI-18=Brief Symptom Inventory-18 Global Severity Index; CAPS-IV=Clinician-Administered PTSD Scale for DSM-IV; NR=not reported; PCL=PTSD Checklist; PCL-M=PTSD Checklist – Military Version; PCL-S=PTSD Checklist-Specific; PTSD=posttraumatic stress disorder; SD=standard deviation; TBI=traumatic brain injury

Table 6 Results from Treatment Studies in Veterans with a History of TBI vs No History of TBI

Study author, year; N; TBI severity | Measure | History of TBI; Change from Pret-reatment mean (SD); n | No History of TBI; Change from Pre-treatment mean (SD); n | Effect Size (ES) [95%CI] Based on mean change from baseline for each group
CPT, Veterans with TBI+PTSD vs PTSD only
Ragsdale 2016^47^; N=20; TBI severity unknown | PCL-S | 16.40 (8.76); n=10 | 11.50 (14.14); n=10 | ES 0.40 [−0.49 to 1.29]
Ragsdale 2016^47^; N=20; TBI severity unknown | BDI-II | 6.30 (7.92); n=10 | 6.80 (10.04); n=10 | ES −0.05 [−0.93 to 0.82]
PE, Veterans with TBI+PTSD vs PTSD only
Ragsdale 2016^47^; N=21; TBI severity unknown | PCL-S | 29.78 (13.65); n=9 | 34.58 (10.34); n=12 | ES −0.39 [−1.26 to 0.49]
Ragsdale 2016^47^; N=21; TBI severity unknown | BDI-II | 16.22 (8.65); n=9 | 17.25 (10.38); n=12 | ES −0.10 [−0.97 to 0.76]
CPT combined with PE, Veterans with TBI+PTSD vs PTSD only
Ragsdale 2016^47^; N=41; TBI severity unknown | PCL-S | 22.74 (12.97) n=19 | 24.09 (16.74) n=22 | ES −0.09 [−0.70 to 0.53]
Ragsdale 2016^47^; N=41; TBI severity unknown | BDI-II | 11.00 (9.52) n=19 | 12.50 (11.32) n=22 | ES −0.14 [−0.75 to 0.47]
PCT, Veterans with TBI vs no TBI history
Bomyea 2017^44^; N=67/mild to moderate TBI | BSI-18 | <10 points | <10 points | ES not estimable, graphed data only. No difference between groups
ACT, Veterans with TBI vs no TBI history
Bomyea 2017^44^; N=62/mild to moderate TBI | BSI-18 | <10 points | <10 points | ES not estimable, graphed data only. No difference moderate TBI between groups
PE combined with PCT, Veterans with TBI+PTSD vs PTSD only
Sripada 2013^48^; N=22/”most” mTBI | CAPS-IV | 36.90 (22.80) | 37.00 (16.80) | ES −0.01 [−0.87 to 0.86]

ACT=Acceptance and Commitment Therapy; BDI-II=Beck Depression Inventory-II; BSI-18=Brief Symptom Inventory-18 Global Severity Index; CPT=Cognitive Processing Therapy; PCL-S=PTSD Checklist-Specific; PCT=Present Centered Therapy; PE=Prolonged Exposure Therapy; PTSD=posttraumatic stress disorder; SD=standard deviation; TBI=traumatic brain injury

Table 7 Strength of Evidence – Key Question 2

Key Question 2: Effectiveness and comparative effectiveness and harms of interventions for psychiatric conditions in service members and Veterans with a history of TBI
Intervention | Number of studies | Strength of evidence | Comments
Behavioral Therapies
Cognitive Processing Therapy (CPT) | 2 | Insufficient overall | - 4 small nonrandomized studies with a pre- and post-study design and 2 small post-hoc analysis of RCTs were evaluated; risk of bias was moderate to high; - Improvements in PTSD and depressive symptom scale scores were observed with all therapies and were consistent across studies where multiple studies existed but lack of usual care or wait-list control group limits interpretation of the effect; - No differences in outcomes regardless of TBI status (history or no history; data from 3 studies) however studies were not specifically designed to examine differential effectiveness by TBI status and were likely underpowered to do so
Prolonged Exposure Therapy (PE) | 3 | Insufficient overall
Acceptance and Commitment Therapy | 1 | Insufficient overall
Present Centered Therapy | 1 | Insufficient overall
PE combined with Present Centered Therapy (PCT) | 1 | Insufficient overall
Non-behavioral Therapies
Hyperbaric oxygen therapy | 1 | Insufficient | - One small pre- and post-study, moderate risk of bias; - Improvement in PTSD symptom scale
Pharmacological | 0 | Insufficient | - No studies identified

PTSD=posttraumatic stress disorder; RCT=randomized controlled trial; TBI=traumatic brain injury

##### Studies of Service Members or Veterans with a History of TBI

One study evaluated a VA TBI-PSTD residential program that incorporated Cognitive Processing Therapy (CPT-Cognitive) in 28 mostly combat Veterans (89%) with a history of mTBI.^45^ The Veterans met criteria for PTSD according to the CAPS-IV. Over one half (57%) had a PTSD service-connected disability. Over 7 weeks, with a mean of 14 sessions, CAPS-IV and PCL-S scores improved significantly from the pre-treatment assessment with better improvement observed with CAPS-IV (Table 5). Symptoms of depression, based on the BDI-II, were also improved compared to pre-treatment (insufficient evidence, Table 7).

A larger study (n=69) evaluated Veterans (74%) and active-duty personnel with PTSD and a history of TBI receiving outpatient (78%) and inpatient Prolonged Exposure (PE) therapy as part of routine clinical care at 2 VA medical centers.^49^ TBI severity was mixed, with 75% mild and 25% moderate to severe. Blast accounted for 51% of the TBIs and the mean number of reported TBIs was 2.8. Diagnosis of PTSD was confirmed by a psychiatrist or psychologist following a positive screen. Over an average of 9.5 sessions, PE therapy was found to improve both PTSD and depressive symptoms with ESs of 1.52 [95%CI 1.14 to 1.90] and 1.03 [95%CI 0.67 to 1.38] for the PCL (version not reported) and the BDI-II, respectively (Table 5). Among the 44 Veterans who completed therapy, these improvements were even greater. Clinically significant changes based on cut-off scores and reliable changes in points were established for both scales. Clinically significant change in symptom severity for the PCL, defined as a pretreatment score of at least 50 points that changed to a score of 49 points or lower and a reliable change of at least 10 points, was achieved by 61% (n=42) of the all the participants and 86% of those who completed therapy. Clinically significant change for the BDI-II, defined as a pretreatment score of at least 15 points that changed to a score of 14 points or lower and a reliable change of at least 5 points, was achieved by 45% of the 69 participants and 55% of the completers (insufficient evidence, Table 7).

An earlier study by Wolf examined 10 male Veterans diagnosed with PTSD with a history of mild/moderate TBI who received outpatient PE therapy.^50^ Over an average of 13 sessions, PE therapy was also found to improve both PTSD and depressive symptoms (Table 5). Clinically significant change was also examined, based on cutoff values halfway between the clinical and nonclinical normative samples on both the PCL-M and BDI-II. Changes in symptom severity were clinically significant if the score changed from above the cutoff pretreatment to below the cutoff posttreatment. Posttreatment scores below 49.5 and 14.9 were identified as clinically significant for the PCL-M and BDI-II, respectively. Based on these thresholds, 9 participants (90%) had clinically significant change and no longer met criteria for PTSD. For the BDI-II, 4 participants (40%) had scores below 14.9 post-treatment, indicating clinically significant reduction in depressive symptoms (insufficient evidence, Table 7).

#### Hyperbaric Oxygen Therapy

One pre-post proof of concept study (n=16) evaluated the impact of HBO_2_ therapy on PCS and PTSD in male participants with a history of mild to moderate TBI characterized by loss of consciousness due to blast injury (Appendix C, Tables 4 and 5).^46^ Eight of the men were active duty and the other 8 were Veterans. Mean number of TBIs due to blast was 2.7. All participants met DSM-IV criteria for PTSD; 15 participants met the PCL-M threshold (≥50) for PTSD. The participants were treated with 1.5 HBO_2_ atmospheres absolute until 40 sessions were completed over a 29-day period. At the post-treatment assessment, pre-treatment scores for PCL-M were reduced from 67 to 47, with an ES of 1.5 [95%CI 0.6 to 2.3] (insufficient evidence, Table 6). There were reports of mild reversible middle ear barotrauma in 5 subjects (one of whom withdrew from the study) and transient deterioration of symptoms (including mood, headaches, and depression) in 4 subjects.

### Summary of Findings

We found no randomized controlled trials (RCTs) that tested the efficacy or effectiveness of interventions for the treatment of psychiatric conditions in service members or Veterans with a history of deployment-related mTBI. We identified 6 studies of behavioral therapies for PTSD, depressive, or anxiety disorders in OEF/OIF/OND service members and Veterans with a history of TBI and one study of hyperbaric oxygen therapy (HBO_2_) for post-concussion syndrome (PCS) and PTSD in service members and Veterans with a history of mild to moderate blast-related TBI. No studies reported on treatments for substance use disorders or suicidal ideation and no studies reported on the effect of pharmacological interventions for the psychiatric conditions of interest in service members or Veterans with and without a history of mTBI.

Five of the studies were small, non-randomized, pre- to post-treatment studies; 2 were secondary analyses of RCTs conducted to test the comparative effectiveness of select behavioral therapies in OEF/OIF/OND Veterans, some of whom had TBI.

Limited evidence from 3 studies (1 pre-post study and 2 secondary analyses of RCTs) suggested that the treatment effects did not vary by TBI status. CPT and PE were associated with similar levels of improvements in PTSD (PTSD Checklist-Specific; PCL-S) and symptoms of depression (Beck Depression Inventory; BDI-II) for Veterans with PTSD who did and did not have a history of TBI of unknown severity. Combined data from groups receiving either PE or PCT showed similar improvement in PTSD symptoms (Clinician Administered PTSD Scale for Diagnostic and Statistical Manual of Mental Disorders, 4^th^ Edition; CAPS-IV) in Veterans with PTSD who also had a history of “mostly” mTBI and those with no history of TBI. Both PCT and ACT resulted in significant but modest reductions in depressive and anxiety symptoms (Brief Symptom Inventory; BSI-18) in Veterans with and without a history of mild to moderate TBI who met criteria for at least one anxiety (including PTSD) or depressive disorder. Quality of life was reported only in the study of PCT and ACT. Mental health component scores improved significantly in both treatment groups; physical health component scores did not. Treatment effects did not vary in Veterans with and without mild to moderate TBI.

Three additional pre-post intervention studies reported outcomes following either CPT or PE for service members or Veterans with PTSD and a history of mild to severe TBI. Compared to baseline, authors reported significantly reduced PTSD (CAPS-IV; PCL [version not specified], PCL-S, or PTSD Checklist-Military [PCL-M]), and depressive (BDI-II) symptoms following treatment. No studies provided data on harms associated with the psychological interventions.

Observed changes in PTSD symptoms scores from baseline to end of psychological intervention exceeded minimal clinically important differences (MCIDs) reported for the PCL-M (5–10 points)^51–53^ and CAPS-IV (10 points).^53,54^ Similarly, observed changes in depressive symptom scores exceeded the MCID reported for the BDI-II (17.5% reduction from baseline).^55^ However, because studies lacked usual care or wait-list controls and were not specifically designed to examine differential effectiveness by TBI status the evidence is insufficient to adequately assess possible differential effectiveness of the interventions in this population (Table 7).

One small, pre-post, uncontrolled, proof-of-concept study of HBO_2_ for PCS and PTSD among service members and Veterans with mild to moderate TBI reported a significant reduction in PCL-M scores following treatment (insufficient evidence, Table 7). There were reports of mild reversible middle ear barotrauma in 5 subjects (one of whom withdrew from the study) and transient deterioration of symptoms (including mood, headaches, and depression) in 4 subjects.