# Methods

## Topic Development

We developed the scope, key questions, inclusion/exclusion criteria, and outcomes of interest with input from the Operational Partners and Technical Expert Panel. The protocol was registered in PROSPERO (CRD42018083990). The report will be used by the Veterans Health Administrative TBI Advisory Committee to inform clinical practice guideline development and by the Office of Research and Development to inform future research priorities.

## Search Strategy

We searched MEDLINE, PsycINFO, the PILOTS database, publications from VA HSR&D, and research from the Defense and Veterans Brain Injury Center (DVBIC) to identify English language observational studies, RCTs, and CCTS published and indexed from 2000 to October 2017. Search terms included Medical Subject Headings (MeSH) and keywords for TBI, psychiatric conditions of interest, service members and Veterans, and service era (Appendix A). Reference lists from relevant systematic reviews and included studies were searched to identify additional eligible studies. Articles identified by the Operational Partners and Technical Expert Panel were also reviewed for inclusion.

## Study Selection

Two investigators or research associates independently reviewed abstracts to identify articles eligible for full text review. Two investigators or research associates then independently reviewed full text articles to determine studies that met inclusion criteria. Conflicts were resolved through discussion or by a third investigator when necessary. Abstract and full text review were done using DistillerSR (Evidence Partners; https://www.evidencepartners.com/).

For Key Question 1a/1b, we included studies that reported prevalence, severity, or symptom persistence of the identified psychiatric conditions in nationally representative or geographically diverse samples of US service members and/or Veterans (OEF/OIF/OND era) with and without a history of mTBI(s) incurred during deployment. If the study included both deployment- and non-deployment related TBI or different severities of TBI, at least 75% of the population must have a history of deployment-related mTBI(s). If study participants had more than one TBI, at least one must have been deployment-related. If the study did not specify severity of TBI(s), typically in a study that determined history of TBI from International Classification of Diseases, Ninth Revision (ICD-9) codes, we included the study because prior research indicates that a high percentage of TBI in OEF/OIF/OND is mTBI.^5^ Results are reported separately for studies with confirmed mTBI(s) and those with TBI unspecified.

For Key Question 2, we included studies of interventions/treatments for the 5 psychiatric conditions of interest (PTSD, depressive disorders, substance use disorders, suicidal ideation or attempts, and anxiety disorders) in US service members and/or Veterans (OEF/OIF/OND era) with mTBI histories.

Reasons for exclusion were documented for articles undergoing full text review. For both Key Questions, we excluded studies: 1) enrolling non-US service members or Veterans, 2) with fewer than 75% of participants from the OEF/OIF/OND service era, 3) with fewer than 75% of participants reporting occurrence of TBI in a deployed environment or specifying that greater than 25% of the sample had a moderate or severe TBI, 4) not reporting on psychiatric conditions of interest, 5) not reporting outcomes of interest (see above), and 6) not using observational or randomized controlled trial designs (eg, case reports, narrative reviews, editorials). Additionally, for Key Questions 1a/1b, we excluded studies 1) enrolling a sample from a single facility (ie, not nationally representative) and 2) reporting prevalence or severity/symptom persistence in a mTBI group without a no-TBI comparison group.

## Data Abstraction

We developed table templates for data abstraction. Data were abstracted by one investigator or research associate and verified by a second.

The following elements were abstracted from each study:

1. Study/population characteristics including study design, age, gender, race, service era, time since injury or discharge, TBI diagnostic method or etiology, and history of TBI.
2. Psychiatric condition(s) including type, severity, condition specific information, and diagnostic tool.
3. Intervention/comparator characteristics (Key Question 2) including length of treatment and/or number of sessions.
4. Outcomes including prevalence, severity, symptom persistence of the psychiatric conditions (Key Question 1), and effectiveness of interventions for the treatment of the psychiatric conditions of interest including clinically important changes in symptoms, harms, and changes in function and quality of life. We noted whether data were from self-report or clinician administered assessments.

## Quality Assessment

Risk of bias for prevalence studies was determined based on sampling methods; reporting of subject and setting characteristics; use of valid, standard methods for case definition and outcomes assessment, and response rate. The criteria were adapted from the Critical Appraisal Checklist for Studies Reporting Prevalence Data developed by the Joanna Briggs Institute (http://joannabriggs.org/research/critical-appraisal-tools.html).^6^

For non-randomized intervention studies, risk of bias was determined based on appropriateness of sampling, completeness of follow-up, use of standard assessment methods, manualized treatment with monitoring of fidelity, and independent outcome assessment. The criteria were adapted from the Joanna Briggs Institute Critical Appraisal Tool for Quasi-Experimental Studies (experimental studies without random allocation) (http://joannabriggs.org/research/critical-appraisal-tools.html).^7^

## Data Synthesis

For Key Question 1, results were qualitatively synthesized. Subsets (eg, active duty vs Veteran, time since TBI(s), gender, age, or severity of psychiatric condition(s)) were considered when feasible. For Key Question 2, data were analyzed using Review Manager Version 5.3 software (Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration). When pre- and post-treatment data were provided, within study effect sizes and corresponding 95% confidence intervals (CIs) were computed using Hedges’ g (adjusted for sample size). The effect sizes can be interpreted using Cohen’s definition of small (0.2), medium (0.5), and large (0.8) effect sizes.^8^ When data were provided, between-group effect sizes and corresponding 95% CIs were computed based on the mean change from baseline for each group.

## Rating the Body of Evidence

We rated overall strength of evidence for 1) the prevalence of the psychiatric conditions based on data from national samples and 2) the effectiveness of interventions for the psychiatric conditions using methods developed by AHRQ and the Effective Health Care Program.^9^ The strength of the evidence was evaluated based on 4 domains: 1) risk of bias (whether the studies for a given outcome or comparison have good internal validity); 2) consistency (the degree of similarity in the effect sizes, ie, same direction of effect, of the included studies); 3) directness (reflecting a single, direct link between the intervention of interest and the outcome); and 4) precision (degree of certainty surrounding an effect estimate of a given outcome).

## Peer Review

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer comments and our responses are presented in Appendix C and the report was modified as needed.