# APPENDIX C Evidence Tables

Table 1 Prevalence and/or Severity of Psychiatric Conditions – National Samples (KQ1)

Table 2 Prevalence and/or Severity of Psychiatric Conditions – Geographically Diverse Samples (KQ1)

Table 3 Risk of Bias for Prevalence Studies (KQ1)

Table 4 Overview of Treatment Studies (KQ2)

Table 5 Outcomes from Treatment Studies (KQ2)

Table 6 Risk of Bias for Treatment Studies (KQ2)