# APPENDIX B Peer Review Comments/Author Responses

Question Text | Reviewer Comment | Author Responses
1) Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you.
1) Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you.
1) Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you.
1) Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you.
1) Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you.
1) Are the objectives, scope, and methods for this review clearly described? | No: Concerned about: Key question 1: suicide attempt and death not being included; key question 2: efficacy not explored | Please see responses under Question 4) below.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
2) Is there any indication of bias in our synthesis of the evidence? | No | Thank you.
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - The report lists only 1 study that examined HBOT for combat-associated TBI and PTSD. The study cited is uncontrolled and not worthy of inclusion while there are results from the 3 military HBOT trials that examine an effect in PTSD. These are RCT’s and worthy of discussion. | The military HBOT trials included service members with a history of TBI and persistent postconcussion symptoms, not PTSD. Our KQ2 was focused on whether treatments for 5 specific psychiatric conditions are effective in individuals who have both the condition and a history of TBI or does the presence of a TBI history limit or moderate treatment effectiveness. Therefore, the military HBOT studies would not have been eligible because participants did not have one of the 5 pre-defined psychiatric conditions of interest for our review. We clarified in the Introduction that the focus of our review is on the specific psychiatric conditions.
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | Yes - The authors say there have been no RCTs of treatment for mental health conditions in TBI. However, there are three that reported PTSD Checklist outcomes following HBOT: Miller, Cifu, and Wolf. Overall, I think the section on treatment could benefit from discussion with the Portland ESP center that did the recent review on HBOT. That review also cites a 4th RCT that was published only as a conference proceeding. | Please see the comment above regarding eligibility of these trials. We reviewed the Portland ESP Evidence Brief on HBOT and cite the report in the Discussion section. We also modified the statements about no RCTs of treatment to specify the psychiatric conditions of interest for our review.
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
3) Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Adequate to outstanding | Thank you.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1) The introduction cites that there is an increase in TBI in wars as a result of improvements in IEDs - is this actually true or simply a continuation of the myth of OEF/OIF? There were significant percentages of TBI in WWII and Vietnam that were unreported, but likely higher than OEF/OIF given the numbers of troop involved, the amount of large ammunition utilized and the high rate of mines/IEDs (in Vietnam). Since >50% of all the TBI’s in OEF/OIF were related to motor vehicle trauma, this would seem to be important to emphasize, not include as an afterthought. | 1) We appreciate the reviewer’s comments. We modified the introduction in both the Executive Summary and full report.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2) I don’t believe the use of the term “psychiatric” disorders and diagnoses is the preferred adjective and would prefer either mental health or psychologic diagnoses/disorders, | 2) In accordance with the Diagnostic and Statistical Manual of Mental Disorders we choose to use the term psychiatric disorders.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3) While it may be a premise of this review, I’m believe that the overwhelming majority of TBI clinicians actually feel that the standard treatments for mental health conditions are safe and effective even in the face of a TBI (given their practice patterns). Again, I am concerned with this report spreading the same misleading myths that the DoD (and certain researchers) have perpetuated. Clinicians that I work with feel comfortable with these treatments, and this review was an attempt to support that practice. | 3) The purpose of our review was to identify and report on the evidence. We do not make recommendations for treatment. At present, there is limited evidence on which clinicians can base treatment decisions.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Please remove all text and table occurrences, as well as the reference for the Harch Hyperbaric oxygen study. | We have added text to emphasize that this is a small, uncontrolled, pre-post study. However, it does meet our eligibility criteria and therefore it would be selective reporting were we to remove it.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The review is well done in many ways, so these comments are meant to help strengthen a good report. | Thank you.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1. In the reviews of prevalence, to what extent is there a problem with the same VA admin data being used in different studies. The data included in two studies focused differently enough to be independent papers could still be non-independent, but appear as two different studies. This would be a much greater problem in meta-analysis in which the Ns were being used for weighting, but it is also a potential problem here in the sense that there may appear to be more supportive evidence than is actually the case if the same people are contributing to findings across studies. | 1. There is clearly overlap. “Study Periods” are reported in column one of Table 2 and in the description of the Sampling Method in Appendix C, Table 1. The population-based studies provide information on the population of VA users within the identified time period (ie, the VA as a population rather than a sample). We comment on the overlap in the Executive Summary and full report.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2. As mentioned specifically in response to the question about excluded studies, I believe there are 3 or 4 excluded RCTs of HBOT. The failure to include the RCTs seems to have resulted in a misstatement about the evidence for HBOT, e.g., p. 10. I cannot see how the inclusion/exclusion criteria would have led to these studies being excluded. If the criteria in fact are responsible, this is a more significant problem. | 2. Please see note above regarding the exclusion of these studies. We also clarified the Study Selection sections in the Executive Summary and full report.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3. Should RCTs that examined TBI status as an effect modifier be summarized differently than studies that simply compare TBI/no TBI in a pre-post design? | 3. The text and tables for Key Question 2 have been rearranged to emphasize the studies with TBI as an effect modifier.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4. P. 12, although 10 points on the CAPS-IV has been validated in multiple studies (e.g., Schnurr & Lunney, 2016), 8 points on the PCL is not an agreed-upon MCID for the PCL. Monson et al (2008), for example, found 10 points to be a good number, and Shiner et al. (2011) found 5 points to be a good number. | 4. Thank you for this information. We modified the statement about the PCL to include a range of values and added the suggested citations to the full report.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5. Is the method of PTSD assessment (clinical admin diagnosis, structured clinical interview, self-report) important in its relation to outcome? | 5. Yes. We now describe the method of assessment for all of the mental health outcomes with greater detail on the Appendix tables.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6. On p. 12, the suggestion to create further study fails to account for ongoing longitudinal studies that could be used to answer important questions TBI and its comorbidities. These studies include the Neurocognition Deployment Health Study (Vasterling), VALOR (Marx & Keane), Mil Cohort Study, and the Marine Resiliency Study. | 6. Thank you for the suggestion. We added this information In the Discussion/Future Research sections of the Executive Summary and full report.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7. P. 15, re the possible reasons for the comorbidity of PTSD and TBI, one additional one is that the same event that could cause a TBI could cause PTSD. I think this is the view that is more predominant in the field. | 7. We modified the Introduction to remove information about reasons for the comorbidity of PTSD and TBI given that this is not the focus of our review.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Overall, I found this to be an excellent review of the current literature relating mTBI to mental health conditions, including, PTSD, depression, substance abuse, anxiety disorders and suicidal ideation (attempt). I found the criteria for inclusion of the studies to be sound and feel that the literature assembled accurately represents the literature. | Thank you.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | As a general comment, I question the use of the phrase “combat-deployed mTBI”. There is no other kind of combat TBI if not incurred during deployment. If this phrase is to refer to either combat-related mTBI OR deployment-related mTBI, I would simply use the latter phrase (deployment-related, as it is almost never specified if the injury was incurred in a combat situation). | We replaced “combat-deployed” with deployment-related. Our study inclusion criteria required that at least 75% of the TBIs were experienced while deployed (not necessarily in a combat role).
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Also, where specific clinical assessment scores are reported, especially for PTSD (CAPS or PCL), it would be helpful to note whether the assessment was for the DSM IV or 5 diagnostic criteria. The scores are not comparable (e.g., scores on CAPS IV ≠ CAPS 5), so it is important to note from which they are derived so the score you report can be put into the proper context. | We verified that all references to the CAPS or PCL include the version (if reported).
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | The following are both editorial and content suggestions throughout the manuscript:
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1. Page 1: The paragraph beginning “The focus of our review”. I would suggest that the fact that the review is focused on mTBI be moved up to the first paragraph and the methodology for presuming mTBI in studies where the severity of the TBI is unspecified be explained only in the methods section. The rationale for this decision as described in this paragraph is unclear. | 1) We revised the Introduction in the Executive Summary and the full report. We agree with including the details of study selection in the Methods section.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2. Page 2, first paragraph. I assumed that the outcomes were for current diagnoses, meaning that the Veterans and SM included in the studies had active psychological conditions. | 2) Yes,
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3. Page 2 Study Selection. I tried to follow the inclusion and exclusion criteria reported here with the flow diagram on page 20 (this is also the case for the main study description). The n’s reported for the various exclusions noted in the figure do not match up with the actual exclusionary criteria. There are more exclusionary criteria on Page 20 than are noted on Page 2. Also, on Page 3, it would be helpful if paragraph beginning on Line 30 describing the exclusions referred to the figure on page 20. | 3) Thank you for pointing this out. We revised the descriptions of the Inclusion and Exclusion criteria in the Executive Summary and main report. They now are aligned with Figure 1.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4. The Executive Summary Tables (page 6 & 9) should use the same legends (page 9 more informative). | 4) We made the suggested change.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5. Page 7 Executive Summary Table 2. Under the comments section, 2nd bullet, “Type of TBI”. Should this be severity of TBI? Type can be confused with etiology. | 5) Thank you – we meant severity.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6. Page 8 Line 12. I do not think that “one reporting similar severity in the groups with a history of mTBI and no TBI” is reported in Table 3. | 6) This was an error on Table 3 – now corrected.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7. Page 11 Line 50 insert either “combat” or “deployment-related” between that and mTBI. | 7) We added “deployment-related”.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 8. Page 12 Line 10. “changed” should be “changes”. | 8) This has been corrected
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9. The important issue of reintegration is first mentioned on Page 11 in the discussion. It feels like it comes out of the blue there because it has not been motivated prior to this. I would suggest moving the issue of reintegration to Page 12 in the Research Gaps/Future Research section. It is critically important that no studies to date have looked at this issue and the need for treatment studies to include this as an outcome measure should be stressed. | 9) Thank you for the suggestion. We deleted the mention of reintegration in the Discussion section and added to the Research Gaps/Future Research section that outcomes should include both functioning and quality of life measures in addition to symptom measures. Reintegration reflects both functioning and quality of life (and more), but in a very specific population during a set period of time. Also, only one study looked at mental health quality of life, so we need more information in this area.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 10. Page 16, Line 45. It doesn’t make sense to have Timing be “Any time post-TBI” because the studies include non-TBI. I am not sure where that time point should be anchored (post-deployment?). | 10) We agree and changed “Timing” to postdeployment
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 11. Page 17, Line 35. “abstract” should be “abstracts” and “were” should be inserted between that and eligible (on next line). | 11) We corrected this sentence.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 12. Page 18, again the exclusion criteria do not follow information on Page 20. | 12) As noted above, we revised the text to align with Figure 1
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 13. Thought the tables reporting the Prevalence and Severity data were great. | 13) Thank you
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 14. Page 36. Sentence on Line 54 is incomplete. “The rate of binge drinking….” | 14) We corrected this sentence.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 15. Page 39 there is reference again to assessment of health status at “varying times post injury”. Relating #10 above. | 15) We changed this to post-deployment.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 16. Page 40. I believe there should be a reference to Figure 2 in the paragraph describing findings for CPT. | 16) Thank you – we modified the KQ2 text and this figure is no longer included.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 17. Page 51–52. Here I feel that you take a step back in the innovation department by simply referring back to current VA/DoD guidelines for the management of PTSD and the other comorbidities, given the limited evidence on the effectiveness of treatments for mental health conditions. These guidelines don’t take advantage of what has been learned through this review. Given that this is the discussion section, I would much rather see some thoughtful, albeit speculative, recommendations regarding the treatment of the common comorbidities. I also don’t believe that TBI should be listed here as a mental health condition because it is the base condition forming the comorbidities as far as this report is concerned. | 17) Thank you for the suggestion. We removed the section on the VA/DoD guidelines. We comment that the studies showed no indication of harms for evidence-based treatments for treatment of PTSD in service members and Veterans with and without a history of TBI.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1) Summaries in executive summary do not sufficiently couch findings in the context of risk of bias findings. At times findings seem to stray from key questions - particularly pertaining to Key Question 2 | 1) We modified summary paragraphs in the Executive Summary and moved the strength of evidence tables closer to the summary text.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2) Was there a reason why suicide attempts or death were not included in key questions? (this seems like a major weakness) - nonetheless some data is reported on SA (pg. 5) - this is confusing | 2) Suicidal ideation was identified by the operational partners as the psychiatric condition of interest for the review. One study reported suicide attempts so we did extract and include that outcome. A review of studies excluded from our review did not find additional reports of “attempts.”
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3) Some concern re: inclusion of up to 25% moderate to severe - as results could certainly be skewed - same with those in which % were not reported | 3) Studies typically enroll a mixed population and in evidence reviews we often use 75% as the threshold. Had we required strict reporting of 100% mTBI, we would have few, if any, eligible studies.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4) Further articulation of the purpose of the studies included - Key Question #1 (particularly if it was not to measure prevalence) would be useful | 4) We noted this in the Overview of Studies for Key Question 1.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5) In terms of Key Question 1 - would be helpful to report throughout if symptoms reported were above clinical cutoffs - see page 5 final bullet (line 46) - this is great | 5) In Appendix C, Tables 1 and 2 we provide information on clinical cut-offs from the KQ1 studies although we note that there is disagreement on clinical cut-offs.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6) In terms of Key Question 2 - would be helpful to report throughout if symptoms were “clinically significant” | 6) In Appendix C, Table 5 we provide information on clinical cut-offs for the KQ2 studies.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | a. Why was simple efficacy not explored? | a. We considered the included studies to be “effectiveness” studies – evaluating the interventions in “real world” settings. We did not exclude any studies of interventions based on whether they were efficacy or effectiveness studies.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | b. Would suggest that the lack of RCTs needs to be further emphasized | b) We note the need for RCTs in the Discussion and Future Research sections.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7) Believe that the word effectiveness is used when efficacy would likely be more correct (see page 10) | 7) We believe that effectiveness is correct – the studies are testing efficacy in “real world’ settings
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | a. same page - term TBI status is confusing | a) We modified and rearranged these statements. We replaced TBI status with “history of TBI”
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 8) Unclear why the team included outcome associated with negative psychiatric outcomes (page 11) - Pugh 2018 | 8) We removed the text referred to in this comment.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 9) With low to no evidence - unclear how team can suggest that therapies are effective and safe - page 11 (this seem like a major weakness) | 9) We modified the Discussion and Applicability section but note that we did find clinically significant differences in outcomes and no reported harms.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 10) Tables are useful; however, would suggest adding citations in those where they are not provided | 10) Thank you. Citations are added in the final report version.
4) Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 11) Research gaps - what other models besides cohort might be appropriate? | 11) We noted that existing registries may contain relevant information.