# APPENDIX A Search Strategies

Table 1 Ovid (MEDLINE) Search Strategy

| Search Terms
1 | exp Veterans/
2 | veteran$.mp.
3 | exp Veterans Health/
4 | (active duty or military or service member$ or soldier$ or national guard or reserv$).mp.
5 | 1 or 2 or 3 or 4
6 | exp Iraq War, 2003–2011/
7 | exp Afghan Campaign 2001-/
8 | (Operation Enduring Freedom or Operation Iraqi Freedom or Operation New Dawn).mp.
9 | 6 or 7 or 8
10 | 5 or 9
11 | (TBI or mTBI or traumatic brain injur$).mp.
12 | exp Brain Injuries, Traumatic/
13 | ((mild adj2 traumatic) or (m adj2 TBI) or (mild adj2 TBI)).mp.
14 | 11 or 12 or 13
15 | 10 and 14
16 | exp Stress Disorders, Post-Traumatic/
17 | (((post-traumatic or posttraumatic) adj2 stress) or PTSD).mp.
18 | exp Depressive Disorder/ or exp Depressive Disorder, Treatment-Resistant/ or exp Depressive Disorder, Major/
19 | depression.mp.
20 | exp Substance-Related Disorders/
21 | suicide.mp. or exp Suicide/ or exp Suicide, Attempted/
22 | exp Suicidal Ideation/
23 | exp Anxiety Disorders/
24 | ((problem adj2 (alcohol or drink$ or drug$ or substance)) or (substance adj2 abuse) or (substance adj2 disorder) or ((alcohol or drug or tobacco) adj2 (abuse or addiction or disorder))).mp
25 | (general adj2 anxiety).mp.
26 | 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
27 | 15 and 26
28 | limit 27 to (English language and humans and yr=“2000 -Current”)

Table 2 PsycINFO Search Strategy

1 | exp Military Personnel/ or exp MILITARY VETERANS/ or Veteran$.mp.
2 | (soldier$ or “service member$” or “national guard” or “active duty” or reserves).mp.
3 | exp Military Deployment/
4 | exp Combat Experience/
5 | (Operation Enduring Freedom or Operation Iraqi Freedom or Operation New Dawn).mp.
6 | exp Traumatic Brain Injury/
7 | (“traumatic brain injur$” or TBI or mTBI).mp.
8 | 1 or 2 or 3 or 4 or 5
9 | 6 or 7
10 | 8 and 9
11 | posttraumatic stress disorder.mp. or exp Posttraumatic Stress Disorder/
12 | exp Major Depression/ or depressive disorder.mp.
13 | depression.mp.
14 | exp Treatment Resistant Depression/
15 | exp “Substance Use Disorder”/ or exp Drug Abuse/
16 | problem drinking.mp. or exp Alcohol Abuse/
17 | (“substance abuse” or “substance disorder” or “tobacco abuse”).mp.
18 | suicidal ideation.mp. or exp Suicidal Ideation/
19 | exp ATTEMPTED SUICIDE/ or exp SUICIDE/ or Suicide.mp.
20 | exp Anxiety Disorders/ or exp Generalized Anxiety Disorder/ or anxiety.mp.
21 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20
22 | 10 and 21
23 | limit 22 to (human and English language and yr=“2000 -Current”)