# Acknowledgments

This topic was developed in response to a nomination by Stuart Hoffman, PhD, Scientific Program Manager for Brain Injury and Senior Scientific Advisor for Brain Injury; Ralph DePalma, MD, FACS, Special Operations Officer; and David X. Cifu, MD, National Director of Physical Medicine and Rehabilitation Program Office and Chair, VHA TBI Advisory Committee, for use by the VHA TBI Advisory Committee to inform clinical practice guideline development and by the Office of Research and Development to inform future research priorities. The scope was further developed with input from the topic nominators (ie, Operational Partners), the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who have requested the report to inform decision-making. They recommend Technical Expert Panel (TEP) participants; assure VA relevance; help develop and approve final project scope and timeframe for completion; provide feedback on draft report; and provide consultation on strategies for dissemination of the report to field and relevant groups.

- Stuart Hoffman, PhD
  Scientific Program Manager for Brain Injury and Senior Scientific Advisor for Brain Injury
  Office of Research and Development
- Ralph DePalma, MD, FACS
  Special Operations Officer
- David X. Cifu, MD
  National Director of Physical Medicine and Rehabilitation Program Office and Chair, VHA TBI Advisory Committee
  Office of Research and Development / Rehabilitation Research and Development Service

## Technical Expert Panel (TEP)

To ensure robust, scientifically relevant work, the TEP guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members are listed below (* indicates person was also a peer reviewer):

- Christine Marx, MD
  Durham VA Medical Center
  Duke University School of Medicine
  Durham, NC
- Regina McGlinchey, PhD*
  VA Boston Healthcare System
  Harvard Medical School
  Boston, MA
- Murray Raskind, MD
  VA Puget Sound Health Care System
  University of Washington School of Medicine
  Seattle, WA
- Paula Schnurr, PhD*
  VA National Center for PTSD
  Geisel School of Medicine – Dartmouth
  White River Junction, VT
- Rodney Vanderploeg, PhD
  James A. Haley Veterans’ Hospital
  University of South Florida.
  Tampa, Florida.

## Peer Reviewers

The Coordinating Center sought input from external peer reviewers to review the draft report and provide feedback on the objectives, scope, methods used, perception of bias, and omitted evidence. Peer reviewers must disclose any relevant financial or non-financial conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Coordinating Center and the ESP Center work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

- Lisa Brenner, PhD
  Denver VA Medical Center
  University of Colorado
  Denver, CO