# REFERENCES

1 VHA Directive 1137 (2017).
2 The GRADE Working Group. Grading of Recommendations Assessment, Development and Evaluation (GRADE). https://www.gradeworkinggroup.org/
3 AHRQ. Evidence-based Practice Center (EPC) Reports. https://www.ahrq.gov/research/findings/evidence-based-reports/index.html
4 Nikolakopoulou A, Higgins JPT, Papakonstantinou T, CINeMA: An approach for assessing confidence in the results of a network meta-analysis. PLoS Med. Apr 2020;17(4):e1003082. doi:10.1371/journal.pmed.1003082 32243458
5 Li W, You F, Wang Q, Shen Y, Wang J, Guo J. Effects of Tai Chi Chuan training on the QoL and psychological well-being in female patients with breast cancer: a systematic review of randomized controlled trials. Front oncol. 2023 2023;13(101568867):1143674. doi:10.3389/fonc.2023.1143674 37197428
6 Ye X-X, Ren Z-Y, Vafaei S, Effectiveness of Baduanjin Exercise on Quality of Life and Psychological Health in Postoperative Patients With Breast Cancer: A Systematic Review and Meta-analysis. Integrative cancer therapies. 2022 2022;21(101128834):15347354221104092. doi:10.1177/15347354221104092 35699146
7 Noetel M, Sanders T, Gallardo-Gomez D, Effect of exercise for depression: systematic review and network meta-analysis of randomised controlled trials. BMJ. 2024 2024;384(8900488, bmj, 101090866):e075847. AI 1.0. Comment in: BMJ. 2024 Feb 14;384:q320 PMID: 38355168 [https://www.ncbi.nlm.nih.gov/pubmed/38355168]. doi:10.1136/bmj-2023-075847 38355154
8 Skelly AC, Chou R, Dettori JR, Noninvasive Nonpharmacological Treatment for Chronic Pain: A Systematic Review Update. 2020 2020;AI 0.7.
9 Sun F, Li L, Wen X, Xue Y, Yin J. The effect of Tai Chi/Qigong on depression and anxiety symptoms in adults with Cancer: A systematic review and meta-regression. Complement Ther Clin Pract. Aug 2024;56:101850. doi:10.1016/j.ctcp.2024.101850 38626582
10 Ni X, Chan RJ, Yates P, Hu W, Huang X, Lou Y. The effects of Tai Chi on quality of life of cancer survivors: a systematic review and meta-analysis. Support Care Cancer. 2019 2019;27(10):3701–3716. doi:10.1007/s00520-019-04911-0 31236699
11 Bower JE, Lacchetti C, Alici Y, Management of Fatigue in Adult Survivors of Cancer: ASCO-Society for Integrative Oncology Guideline Update. J Clin Oncol. Jul 10 2024;42(20):2456–2487. doi:10.1200/JCO.24.00541 38754041
12 Kang H, Yang M, Li M, Xi R, Sun Q, Lin Q. Effects of different parameters of Tai Chi on the intervention of chronic low back pain: A meta-analysis. PLoS ONE. 2024;19(7):e0306518. doi:10.1371/journal.pone.0306518 38980862
13 Gross A, Kay TM, Paquin JP, Exercises for mechanical neck disorders. Cochrane Database of Systematic Reviews. 2015 2015;(1)AI 0.9. doi:10.1002/14651858.CD004250.pub5
14 Ngai SPC, Jones AYM, Tam WWS. Tai Chi for chronic obstructive pulmonary disease (COPD). Cochrane Database of Systematic Reviews. 2016 2016;(6)AI 1.0. doi:10.1002/14651858.CD009953.pub2
15 Wu S, Wang L, He Y, Effects of different mind-body exercises on glucose and lipid metabolism in patients with type 2 diabetes: A network meta-analysis. Complementary Therapies in Clinical Practice. 2023 2023;53(101225531):101802. doi:10.1016/j.ctcp.2023.101802 37769432
16 Pillay J, Gaudet LA, Saba S, Falls prevention interventions for community-dwelling older adults: systematic review and meta-analysis of benefits, harms, and patient values and preferences. Syst Rev. Nov 26 2024;13(1):289. doi:10.1186/s13643-024-02681-3 39593159
17 Buto MSdS, de Oliveira MPB, Carvalho C, Vassimon-Barroso V, Takahashi ACdM. Effect of complementary therapies on functional capacity and quality of life among prefrail and frail older adults: A systematic review of randomized controlled trials. Archives of gerontology and geriatrics. 2020 2020;91(8214379, 7ax):104236. AI 1.0. doi:10.1016/j.archger.2020.104236 32860990
18 Chen X, Savarese G, Cai Y, Tai chi and qigong practices for chronic heart failure: a systematic review and meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2020/01/01/ 2020;2020
19 Ching SM, Mokshashri NR, Kannan MM, Effects of qigong on systolic and diastolic blood pressure lowering: a systematic review with meta-analysis and trial sequential analysis. BMC Complement Med Ther. 2021 2021;21(1):8. doi:10.1186/s12906-020-03172-3 33407414
20 Zhong D, Li J, Yang H, Tai Chi for Essential Hypertension: a Systematic Review of Randomized Controlled Trials. Curr Hypertens Rep. 2020 2020;22(3):25. doi:10.1007/s11906-020-1031-y 32124064
21 Yang M, Yang J, Gong M, Luo R, Lin Q, Wang B. Effects of Tai Chi on Sleep Quality as Well as Depression and Anxiety in Insomnia Patients: A Meta-Analysis of Randomized Controlled Trials. Int J Environ Res Public Health. 2023 2023;20(4)doi:10.3390/ijerph20043074
22 Hu L, Wang Y, Liu X, Tai Chi exercise can ameliorate physical and mental health of patients with knee osteoarthritis: systematic review and meta-analysis. Clinical rehabilitation. 2021 2021;35(1):64–79. doi:10.1177/0269215520954343 32954819
23 Wang Y, Zhang Q, Li F, Li Q, Jin Y. Effects of tai chi and Qigong on cognition in neurological disorders: A systematic review and meta-analysis. Geriatric Nursing. 2022/08/01/ 2022;46:166–77.35704955
24 Liu S, Wu S, Qi J, Wang L. Effect of traditional Chinese fitness exercises on bone mineral density in postmenopausal women: a network meta-analysis of randomized controlled trials. Front Endocrinol (Lausanne). 2024 2024;15(101555782):1323595. doi:10.3389/fendo.2024.1323595 38390196
25 Su JJ, Lin RSY, Batalik L, Effects of mind-body exercise on physical and psychosocial well-being of stroke patients: A systematic review and network meta-analysis. Geriatr Nurs. 2024 2024;55(8309633, FW7):346–353. AI 0.6. doi:10.1016/j.gerinurse.2023.12.011 38159477
26 Lyu D, Wang J, Yang F, Effect of Tai Chi on post-stroke non-motor disorders: a systematic review and meta-analysis of randomized controlled trials. Clinical rehabilitation. 2021 2021;35(1):26–38. doi:10.1177/0269215520951020 32808532
27 Lyu D, Lyu X, Zhang Y, Tai Chi for Stroke Rehabilitation: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. Front Physiol. 2018 2018;9(101549006):983. doi:10.3389/fphys.2018.00983 30090071
28 Mudano AS, Tugwell P, Wells GA, Singh JA. Tai Chi for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2019 2019;(9)AI 1.0. doi:10.1002/14651858.CD004849.pub2
29 Niu K, Liu Y-L, Yang F, Wang Y, Zhou X-Z, Qu Q. Efficacy of traditional Chinese exercise for sarcopenia: A systematic review and meta-analysis of randomized controlled trials. Front Neurosci. 2022 2022;16(101478481):1094054. AI 0.9. doi:10.3389/fnins.2022.1094054 36620459
30 Zheng W, Li Q, Lin J, Tai Chi for schizophrenia: A systematic review. [References].DP - 2016. Shanghai Archives of Psychiatry. 2016 2016;(4):185–194. AI 1.0.28638191
31 Wayne PM, Berkowitz DL, Litrownik DE, Buring JE, Yeh GY. What do we really know about the safety of tai chi?: A systematic review of adverse event reports in randomized trials. Arch Phys Med Rehabil. Dec 2014;95(12):2470–83. doi:10.1016/j.apmr.2014.05.005 24878398